# APPENDIX K HEALTH DISPARITIES IN VETERANS WITH A MENTAL HEALTH CONDITION

Table Health Disparities in Veterans with a Mental Health Condition

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Ahmadi, 2011: Post-traumatic stress disorder, coronary atherosclerosis, and mortality^325^ | Cardiovascular disease | 637 | Quality | Coronary calcium levels | Yes | 1
Ahmadi, 2011: Post-traumatic stress disorder, coronary atherosclerosis, and mortality^325^ | Cardiovascular disease | 637 | Health Outcome | Cardiovascular mortality | Yes | 1
Banerjea, 2007: Chronic illness with complexities: Mental illness and substance use among Veteran clinic users with diabetes^78^ | Diabetes, co-occurring substance use and mental health disorders in patients with diabetes | 485893 | Health Outcome | Mental health status, substance use disorder, combined mental health and substance use disorder, access to care, and diabetes-related health complications | Yes | 3
Boehmer, 2016: Dental care in an equal access system valuing equity: Are there racial disparities?^83^ | Dental | 71315 | Quality | Receipt of root canal vs extraction | Mixed/Unclear | 0
Borrero, 2013: Adherence to hormonal contraception among women Veterans: differences by race/ethnicity and contraceptive supply^85^ | Women's health (hormonal contraceptives) | 6946 | Health Outcome | Adherence to hormonal contraceptive medication (time between refills, total months of contraceptive coverage, whether the woman had contraceptive coverage during the last week of FY 2008) | Yes | 1
Burnett-Zeigler, 2011: Perceptions of quality of health care among Veterans with psychiatric disorders^267^ | Mental health, Quality of Care | 55578 | Quality | Perception of quality of care | Mixed/Unclear | 1
Butt, 2006: Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects^93^ | HCV, HIV | 6502 | Quality | Prescribed treatment for HCV | Yes | 1
Chan, 2009: Health care utilization and its costs for depressed Veterans with and without comorbid PTSD symptoms^326^ | Mental health (Depression) | 606 | Utilization | Utilization (outpatient, general medical, mental health, inpatient, antidepressant use) | Mixed/Unclear | 1
Cohen, 2010: Maintenance of risk factor control in diabetic patients with and without mental health conditions after discharge from a cardiovascular risk reduction clinic^326^ | Diabetes | 231 | Quality | Hemoglobin A1c level, blood pressure | No | 0
Cohen, 2010: Mental health diagnoses and utilization of VA non-mental health medical services among returning Iraq and Afghanistan Veterans^270^ | Mental health, Utilization | 249440 | Utilization | Outpatient non-mental health services, primary care, medical subspecialty, ancillary services, laboratory tests/diagnostic procedures, emergency services, and hospitalizations | No | 3
Copeland, 2011: Ethnicity and race variations in receipt of surgery among Veterans with and without depression^103^ | Surgery, Mental health (Depression) | 309068 | Quality | Coronary artery bypass graft (CABG), vascular, hip/knee, or digestive system surgeries | Yes | 2
Copeland, 2015: Serious mental illnesses associated with receipt of surgery in retrospective analysis of patients in the Veterans Health Administration^327^ | Mental health (serious mental illness) | 321131 | Quality | Qualifying inpatient operations were invasive procedures requiring either preoperative or immediate (same-day) postoperative hospitalization with at least one overnight. For patients with multiple qualifying operations, the first surgery during the study period FY2006-FY2009 was used. | No | 3
Curran, 2009: Individual and program predictors of attrition from VA substance use treatment^105^ | Mental health (substance use disorder) | 8064 | Quality | Rates of attrition | Mixed/Unclear | 1
Damon, 2015: Access to PTSD care among Veterans with and without substance use diagnoses^329^ | Mental health (PTSD and substance use disorders) | 424211 | Utilization | Utilization of specialty mental health services | Yes | 3
Damon, 2015: Access to PTSD care among Veterans with and without substance use diagnoses^329^ | Mental health (PTSD and substance use disorders) | 424211 | Quality | Attended recommended number of psychotherapy sessions | Yes | 3
Desai, 2006: Case-finding for depression among medical outpatients in the Veterans Health Administration^274^ | Mental health (Depression) | 21489 | Quality | Depression screening | Yes | 2
Dobie, 2006: Posttraumatic stress disorder screening status is associated with increased VA medical and surgical utilization in women^328^ | Mental health (PTSD) | 2578 | Utilization | Primary care, subspecialty clinics, ancillary care, surgical procedures, ED visits | Mixed/Unclear | 2
Dobie, 2006: Posttraumatic stress disorder screening status is associated with increased VA medical and surgical utilization in women^328^ | Mental health (PTSD) | 2578 | Quality | Outpatient diagnostic tests | Yes | 2
Doran, 2013: What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration^275^ | Utilization (ED) | 5531379 | Utilization | VHA ED utilization | Yes | 3
Duffy, 2012: Risk of smoking and receipt of cessation services among Veterans with mental disorders^111^ | Smoking cessation | 224193 | Quality | Physician advised quitting, physician recommended medication, physician discussed quitting methods | Mixed/Unclear | 3
Egede, 2010: Longitudinal differences in glycemic control by race/ethnicity among Veterans with type 2 diabetes^112^ | Diabetes | 8813 | Quality | Mean change in A1c; odds of poor control (A1c >8%) | Yes | 0
Egede, 2011: Longitudinal ethnic differences in multiple cardiovascular risk factor control in a cohort of US adults with diabetes^113^ | Cardiovascular disease, Diabetes | 11203 | Quality | Cardiovascular risk factor control (glycemic, BP, LDL-C) | No | 1
Egede, 2013: Differential impact of longitudinal medication non-adherence on mortality by race/ethnicity among Veterans with diabetes^117^ | Diabetes | 629563 | Health Outcome | Medication non-adherence associated mortality | Mixed/Unclear | 3
Elhai, 2008: Outpatient medical and mental healthcare utilization models among military Veterans: results from the 2001 National Survey of Veterans^33^ | Utilization (outpatient medical and mental health) | 20048 | Utilization | Number of outpatient healthcare visits (VA and non-VA) and receipt of mental health services | Yes | 2
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Utilization | Mental health utilization (outpatient, inpatient, residential) | Mixed/Unclear | 2
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Health Outcome | GAF, self-reported mental health (BASIS-24) | No | 2
Frayne, 2010: Mental illness-related disparities in length of stay: algorithm choice influences results^329^ | Mental health, Utilization | 92255 | Utilization | Average length of stay | Yes | 1
Frayne, 2011: Medical care needs of returning Veterans with PTSD: their other burden^330^ | Mental health (PTSD) | 90558 | Health Outcome | Mean number of medical conditions (comorbidities) | Yes | 2
Ganzini, 2010: End-of-life care for Veterans with schizophrenia and cancer^331^ | End-of-life care | 256 | Quality | Quality of end-of-life care in Veterans with cancer | No | 0
Garfield, 2011: Factors associated with receipt of adequate antidepressant pharmacotherapy by VA patients with recurrent depression^285^ | Mental health (Depression) | 26770 | Quality | Receipt of some antidepressant therapy, adequate acute-phase pharmacotherapy, and adequate continuation-phase pharmacotherapy | Mixed/Unclear | 1
Gerber, 2015: Hormone therapy use in women Veterans accessing Veterans Health Administration care: a national cross-sectional study^130^ | Women's health (hormone therapy) | 157195 | Quality | Prescription of hormone therapy | Yes | 3
Greenawalt, 2013: Posttraumatic stress disorder and odds of major invasive procedures among U.S. Veterans Affairs patients^332^ | Mental health (PTSD) | 501489 | Quality | Odds of invasive hip/knee, digestive system, coronary artery bypass graft (CABG)/percutaneous coronary intervention, and vascular procedures | Yes | 3
Hawkins, 2012: Prevalence, predictors, and service utilization of patients with recurrent use of Veterans Affairs substance use disorder specialty care^293^ | Mental health (substance use disorder) | 1640 | Utilization | Utilization of substance use disorder specialty services following an index encounter | Mixed/Unclear | 0
Heidenreich, 2009: Disparities in VA heart failure care^148^ | Cardiovascular (heart failure) | NR - likely large | Health Outcome | Mortality, rehospitalization | Yes | 2
Heidenreich, 2009: Disparities in VA heart failure care^148^ | Cardiovascular (heart failure) | NR - likely large | Quality | Guideline concordant heart failure care | No | 2
Higgins, 2014: Persistent pain and comorbidity among Operation Enduring Freedom/Operation Iraqi Freedom/Operation New Dawn Veterans^149^ | Pain (chronic) | 5242 | Health Outcome | Persistent pain (either self-rated scale, ICD-9 pain diagnosis, pain clinic visit, or opioid prescription) | Yes | 1
Himelhoch, 2007: Understanding associations between serious mental illness and HIV among patients in the VA health system^335^ | HIV | 279590 | Health Outcome | HIV diagnosis | No | 3
Hunter, 2015: Health care utilization patterns among high-cost VA patients with mental health conditions^336^ | Mental health | 261515 | Utilization | Inpatient (number, LOS [behavioral, residential-domiciliary, medical-surgical, long-term care]), and outpatient (mental health, ED, primary care, specialty) utilization | Mixed/Unclear | 3
Ilgen, 2009: Exploratory data mining analysis identifying subgroups of patients with depression who are at high risk for suicide^157^ | Mental health (Depression) | 887869 | Health Outcome | Suicide | Yes | 2
Ilgen, 2010: Psychiatric diagnoses and risk of suicide in Veterans^296^ | Mental health (multiple) | 3291891 | Health Outcome | Suicide | Mixed/Unclear | 3
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/rehospitalization | Yes | 1
Kaplowitz, 2006: Health care utilization and receipt of cholesterol testing by Veterans with and those without mental illness^333^ | Cardiovascular (lipid management) | 64490 | Quality | Cholesterol screening | Yes | 2
Kazerooni, 2014: Predictors of adherence to hormonal contraceptives in a female Veteran population^165^ | Women's health (hormonal contraceptives) | 805 | Health Outcome | Adherence to hormonal contraceptive medication (medication possession ratio >.9) | No | 0
Kilbourne, 2006: Access to and satisfaction with care comparing patients with and without serious mental illness^334^ | Mental health (serious mental illness) | 7187 | Quality | Self-report ratings on access to and satisfaction with care questions from the LHSV | Yes | 1
Kilbourne, 2006: Quality of care for substance use disorders in patients with serious mental illness^167^ | Mental health (substance use disorder) | 8083 | Quality | Identification of substance use disorders, initiation of treatment, engagement in treatment | Mixed/Unclear | 1
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Quality | Receipt of HCV testing, notified ≤60 days | Mixed/Unclear | 2
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Health Outcome | HCV positive | Mixed/Unclear | 2
Kilbourne, 2008: Quality of care for cardiovascular disease-related conditions in patients with and without mental disorders^169^ | Cardiovascular (hyperlipidemia screening) | 46430 | Quality | Hyperlipidemia screening, receipt of a foot exam, eye exam, renal test, and hemoglobin A1c >9 | Mixed/Unclear | 2
Kilbourne, 2009: Are VA patients with serious mental illness dying younger?^335^ | Mental health (serious mental illness) | 5000888 | Health Outcome | Mortality (all-cause and heart disease-specific), years of potential life lost (YPLLs) | Mixed/Unclear | 3
Kilbourne, 2009: Excess heart-disease-related mortality in a national study of patients with mental disorders: identifying modifiable risk factors^336^ | Cardiovascular | 147193 | Health Outcome | Heart disease mortality | Mixed/Unclear | 3
Kodl, 2010: Mental health, frequency of healthcare visits, and colorectal cancer screening^337^ | Cancer (colorectal) | 885 | Quality | Colorectal cancer screening | Yes | 0
Krein, 2006: Diabetes treatment among VA patients with comorbid serious mental illness^338^ | Diabetes | 36546 | Utilization | Inpatient, outpatient utilization | No | 1
Krein, 2006: Diabetes treatment among VA patients with comorbid serious mental illness^338^ | Diabetes | 36546 | Quality | HbA1c screening, high-risk HbA1c, LDL-C screening, high risk LDL-C, cholesterol screening | No | 1
Lehavot, 2013: Barriers to care for women Veterans with posttraumatic stress disorder and depressive symptoms^339^ | Mental health | 3593 | Quality | Reported unmet healthcare needs | Yes | 0
Lehavot, 2015: Posttraumatic stress disorder symptom severity and socioeconomic factors associated with Veterans Health Administration use among women Veterans^344^ | Mental health, General VA use | 617 | Utilization | Utilization of VA healthcare within past year | Mixed/Unclear | 0
Lund, 2013: Patient and Facility Characteristics Associated with Benzodiazepine Prescribing for Veterans with PTSD^300^ | Mental health (PTSD) | 495309 | Quality | Benzodiazepine prescription | Yes | 3
Lynch, 2014: Impact of medical and psychiatric multi-morbidity on mortality in diabetes: emerging evidence^340^ | Diabetes | 625903 | Health Outcome | Mortality | Yes | 2
Maguen, 2013: The relationship between body mass index and mental health among Iraq and Afghanistan Veterans^341^ | Mental health, BMI | 496722 | Quality | BMI | Yes | 3
Mattocks, 2015: Infertility care among OEF/OIF/OND women Veterans in the Department of Veterans Affairs^187^ | Women's health (Reproductive health) | 1323 | Quality | Received an infertility assessment | No | 0
Morden, 2010: Quality of care for cardiometabolic disease: associations with mental disorder and rurality^342^ | Cardiovascular (hypertension) | 23780 | Quality | Blood pressure control, poor blood pressure, Foot exam, retinal exam, renal testing, hemoglobin A1c >9, LDL-C <100, blood pressure control | Mixed/Unclear | 2
Morden, 2012: Eight-year trends of cardiometabolic morbidity and mortality in patients with schizophrenia^343^ | Mental health (schizophrenia), Cardiometabolic illness | 130724 | Quality | Hypertension, BMI >30kg/m2, dyslipidemia | Mixed/Unclear | 2
Morden, 2012: Eight-year trends of cardiometabolic morbidity and mortality in patients with schizophrenia^343^ | Mental health (schizophrenia), Cardiometabolic illness | 130724 | Health Outcome | Diabetes, coronary artery disease, mortality | Mixed/Unclear | 2
Nelson, 2011: Adherence to antihyperlipidemic medication and lipid control in diabetic Veterans Affairs patients with psychotic disorders^344^ | Diabetes | 124 | Quality | Adherence, lipid control | Mixed/Unclear | -1
Nelson, 2011: Medication adherence and glycemic control in patients with psychotic disorders in the Veterans Affairs healthcare system^345^ | Mental health (serious mental illness) | 124 | Quality | Medication adherence, glycemic control | No | -1
Partin, 2010: The interrelationships between and contributions of background, cognitive, and environmental factors to colorectal cancer screening adherence^351^ | Cancer (colorectal) | 2416 | Quality | Colorectal cancer screening adherence | No | 1
Phillips, 2015: Racial/ethnic disparities in monitoring metabolic parameters for patients with schizophrenia receiving antipsychotic medications^200^ | Mental health (serious mental illness) | 30258 | Quality | Monitoring of metabolic dysregulation | Mixed/Unclear | 1
Plomondon, 2007: Severe mental illness and mortality of hospitalized ACS patients in the VHA^352^ | Cardiovascular (Acute Coronary Syndrome) | 14194 | Health Outcome | 1-year all-cause mortality, combined 1-year all-cause mortality/re-hospitalization | No | 2
Pugh, 2008: Potentially inappropriate prescribing for the elderly: effects of geriatric care at the patient and health care system level^206^ | Geriatrics, prescribing | 850154 | Quality | Potentially inappropriate prescribing in the elderly | Yes | 3
Runnals, 2013: Self-reported pain complaints among Afghanistan/Iraq era men and women Veterans with comorbid posttraumatic stress disorder and major depressive disorder^303^ | Pain, Mental health (PTSD, MDD) | 1614 | Health Outcome | Pain: back, muscle, and headaches | Yes | 0
Ryan, 2015: Predicting utilization of healthcare services in the Veterans Health Administration by returning women Veterans: The role of trauma exposure and symptoms of posttraumatic stress^353^ | Mental health, Utilization | 133 | Utilization | VHA service utilization | Mixed/Unclear | 1
Sajatovic, 2006: Self-reported medication treatment adherence among Veterans with bipolar disorder^304^ | Mental health (bipolar) | 184 | Quality | Self-report of medication adherence | No | 0
Sambamoorthi, 2012: Decomposing gender differences in low-density lipoprotein cholesterol among Veterans with or at risk for cardiovascular illness^219^ | Cardiovascular (lipid management) | 527568 | Quality | LDL-C greater than or equal to 130 | Mixed/Unclear | 3
Seal, 2011: Substance use disorders in Iraq and Afghanistan Veterans in VA healthcare, 2001-2010: Implications for screening, diagnosis and treatment^226^ | Mental health (substance use disorder) | 456502 | Health Outcome | Presence or absence of substance use disorders (alcohol or drug use disorder) | Yes | 3
Seyfried, 2011: Predictors of suicide in patients with dementia^308^ | Dementia | 294952 | Health Outcome | Suicide | Mixed/Unclear | 3
Shaw, 2014: Posttraumatic stress disorder and risk of spontaneous preterm birth^227^ | Women's health (PTSD, preterm birth) | 16334 | Health Outcome | Spontaneous preterm birth | Yes | 1
Sullivan, 2015: Influence of schizophrenia diagnosis on providers' practice decisions^346^ | Mental health (schizophrenia) | 275 | Quality | Likelihood of referral to weight reduction, pain management, sleep study | Mixed/Unclear | 1
Taveira, 2008: Efficacy of a pharmacist-led cardiovascular risk reduction clinic for diabetic patients with and without mental health conditions^347^ | Cardiovascular | 297 | Quality | Total cholesterol, LDL-C, hemoglobin A1c, SBP, | Mixed/Unclear | -1
Trief, 2006: Post-traumatic stress disorder and diabetes: co-morbidity and outcomes in a male Veterans sample^348^ | Diabetes | 14438 | Quality | Hemoglobin A1c level, cholesterol, weight, BMI | Mixed/Unclear | 2
Trief, 2006: Post-traumatic stress disorder and diabetes: co-morbidity and outcomes in a male Veterans sample^348^ | Diabetes | 14438 | Health Outcome | Depression, substance use disorder diagnoses | Yes | 2
Tseng, 2007: The association between mental health functioning and nontraumatic lower extremity amputations in Veterans with diabetes^237^ | Diabetes | 114890 | Health Outcome | Major and minor non-traumatic lower extremity amputations | Mixed/Unclear | 3
Weitlauf, 2013: Receipt of cervical cancer screening in female Veterans: impact of posttraumatic stress disorder and depression^349^ | Cancer (cervical) | 34123 | Quality | Cervical cancer screening | Mixed/Unclear | 2
Yee, 2011: Mental illness: is there an association with cancer screening among women Veterans?^350^ | Cancer (breast) | 606 | Quality | Breast cancer screening, colon cancer screening (fecal occult blood test in 3 years, flexible sigmoidoscopy in 5 years, or colonoscopy in 10 years), cervical cancer screening (pap smear 1-3 years) | Mixed/Unclear | 0
Zivin, 2007: Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: Associations with patient and treatment setting characteristics^254^ | Mental health (Depression) | 807694 | Health Outcome | Suicide mortality | Mixed/Unclear | 3