# APPENDIX J HEALTH DISPARITIES AMONG WOMEN

Table Health Disparities Among Female Veterans

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Aliaga, 2007: Mental health encounters and diagnoses following deployment to Iraq and/or Afghanistan, US Armed Forces, 2001–2006^263^ | Mental health | 865664 | Health Outcome | One or more mental disorder diagnosis | Yes | 2
Alston, 2014: Assistive technology and Veterans with severe disabilities: examining the relationships among race, personal factors, medical support, income support, and use^72^ | Disability | 16313 | Quality | Use of assistive technology by disabled Veterans | No | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 5500392 | Quality | Proportion screened for HCV | No | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 5500392 | Health Outcome | HCV infection prevalence | No | 2
Banerjea, 2007: Chronic illness with complexities: mental illness and substance use among Veteran clinic users with diabetes^78^ | Diabetes, co-occurring substance use and mental health disorders in patients with diabetes | 485893 | Health Outcome | Mental health status, substance use disorder, combined mental health and substance use disorder, access to care, and diabetes-related health complications | Mixed/Unclear | 3
Bean-Mayberry, 2009: Does sex influence immunization status for influenza and pneumonia in older Veterans^81^ | Preventive care (immunization status) | 48424 | Quality | Receipt of influenza immunization in the prior influenza season and receipt of pneumonia immunization ever | Yes | 2
Bernardy, 2013: Gender differences in prescribing among Veterans diagnosed with posttraumatic stress disorder^264^ | Mental health (PTSD) | 495309 | Quality | Atypical antipsychotics, benzodiazepine, and SSRI/SNRI prescribing | Mixed/Unclear | 3
Bierman, 2007: Sex differences in inappropriate prescribing among elderly Veterans^82^ | Geriatrics, Prescribing | 965756 | Quality | Zhan criteria for inappropriate prescribing for older adults. | Yes | 3
Blackstock, 2013: Sex disparities in overall burden of disease among HIV-infected individuals in the Veterans Affairs healthcare system^265^ | HIV | 8300 | Quality | Overall burden of disease was measured using the VACS Index, an index that incorporates HIV (eg, CD4 cell count) and non-HIV biomarkers (eg, hemoglobin) and is highly predictive of all-cause mortality. | Yes | 1
Boehmer, 2016: Dental care in an equal access system valuing equity: are there racial disparities?^83^ | Dental | 71315 | Quality | Receipt of root canal vs extraction | No | 0
Borrero, 2006: Brief report: Gender and total knee/hip arthroplasty utilization rate in the VA system^266^ | Pain (total knee/hip arthroplasty) | 329461 | Quality | Undergoing knee or hip TJA within 2 years | No | 3
Burnett-Zeigler, 2011: Perceptions of quality of health care among Veterans with psychiatric disorders^267^ | Mental health (multiple) | 55578 | Quality | Perception of quality of care | No | 1
Butt, 2006: Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects^93^ | HCV, HIV | 6502 | Quality | Prescribed treatment for HCV | No | 1
Carlson, 2013: Headache diagnoses among Iraq and Afghanistan war Veterans enrolled in VA: a gender comparison^268^ | Pain (Headache) | 470215 | Health Outcome | Prevalence and type of headache diagnosis | Mixed/Unclear | 3
Chatterjee, 2009: Gender differences in Veterans health administration mental health service use: Effects of age and psychiatric diagnosis^269^ | Mental health (multiple) | 782789 | Utilization | Mental health utilization (any mental health service within the VHA and any specialty mental health services in the VHA | Mixed/Unclear | 3
Cohen, 2010: Mental health diagnoses and utilization of VA non-mental health medical services among returning Iraq and Afghanistan Veterans^270^ | Mental health, utilization | 249440 | Utilization | Outpatient non-mental health services, primary care, medical subspecialty, ancillary services, laboratory tests/diagnostic procedures, emergency services, and hospitalizations | Mixed/Unclear | 3
Cone, 2011: Demographic determinants of response to statin medications^101^ | Cardiovascular (coronary artery disease) | 5191 | Quality | Achieving goal of LDL-C <100 | Yes | 0
Copeland, 2008: Treatment adherence and illness insight in Veterans with bipolar disorder^102^ | Mental health (Bipolar) | 435 | Quality | Medication adherence (Morisky scale, no missed doses) | Yes | 0
Copeland, 2014: Prevalence of suicidality among Hispanic and African American Veterans following surgery^104^ | Mental health, surgery (organ, bone or joint, cancers, vascular, and amputations) | 89995 | Health Outcome | Diagnosis of suicidal behavior or ideation | No | 2
Curran, 2009: Individual and program predictors of attrition from VA substance use treatment^105^ | Mental health (substance use disorder) | 8064 | Quality | Rates of attrition | Yes | 1
Currie, 2008: An investigation of the quantity and type of female Veterans' responses to hepatitis C treatment screening and acceptance^271^ | HCV | 4201 | Quality | HCV treatment screening | No | 0
Curry, 2014: Lifetime major depression and comorbid disorders among current-era women Veterans^272^ | Mental health (Depression) | 1700 | Health Outcome | Lifetime major depressive disorder (MDD), rates of comorbid disorders | Mixed/Unclear | 0
Davis, 2014: Utilization of VA mental health and primary care services among Iraq and Afghanistan Veterans with depression: the influence of gender and ethnicity status^273^ | Mental health (Depression) | 1556 | Utilization | Use of VA mental health and primary care services, prescription of antidepressants | Mixed/Unclear | 1
Desai, 2006: Case-finding for depression among medical outpatients in the Veterans Health Administration^274^ | Mental health (Depression) | 21489 | Utilization | Depression screening, screening positive, follow-up evaluation, and subsequent diagnosis. | No | 2
Doran, 2013: What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration^275^ | Utilization (ED) | 5531379 | Utilization | VHA ED utilization | No | 3
Duffy, 2012: Risk of smoking and receipt of cessation services among Veterans with mental disorders^111^ | Smoking cessation | 224193 | Quality | Physician advised quitting, physician recommended medication, physician discussed quitting methods | No | 3
Duggal, 2010: Comparison of outpatient health care utilization among returning women and men Veterans from Afghanistan and Iraq^276^ | Utilization (outpatient) | 1620 | Utilization | Outpatient utilization (basic, specialty, ancillary) | No | 1
Egede, 2010: Longitudinal differences in glycemic control by race/ethnicity among Veterans with type 2 diabetes^112^ | Diabetes | 8813 | Quality | Mean change in A1c; odds of poor control (A1c >8%) | No | 0
Egede, 2011: Longitudinal ethnic differences in multiple cardiovascular risk factor control in a cohort of US adults with diabetes^113^ | Cardiovascular disease, Diabetes | 11203 | Quality | CV risk factor control (glycemic, BP, LDL-C) | No | 1
Egede, 2013: Differential impact of longitudinal medication non-adherence on mortality by race/ethnicity among Veterans with diabetes^117^ | Diabetes | 629563 | Health Outcome | Medication non-adherence associated mortality | No | 3
Eisen, 2012: Mental and physical health status and alcohol and drug use following return from deployment to Iraq or Afghanistan^277^ | Physical and mental health status | 596 | Health Outcome | Mental health functioning, physical health functioning, alcohol use, drug use | No | 0
Elhai, 2008: Outpatient medical and mental healthcare utilization models among military Veterans: results from the 2001 National Survey of Veterans^33^ | Utilization (outpatient medical and mental health) | 20048 | Utilization | Number of outpatient healthcare visits (VA and non-VA) and receipt of mental health services | Yes | 2
Ellis, 2013: Factors associated with delays in seeking treatment for stroke care in Veterans^120^ | Cardiovascular (Stroke) | 100 | Utilization | Delay in seeking care for treatment for stroke care | No | 1
El-Serag, 2014: Racial differences in the progression to cirrhosis and hepatocellular carcinoma in HCV-infected Veterans^121^ | HCV, cancer (liver) | 149407 | Health Outcome | Risk of cirrhosis or hepatocellular cancer | No | 3
Ersek, 2013: A nationwide study comparing end-of-life care for men and women Veterans^278^ | End-of-life care | 36618 | Quality | Receipt of optimal EOL care (frequency of discussion of treatment goals with a family member, receipt of palliative consult, bereavement contact, and chaplain contact with a family member), family member ratings of care | No | 2
Farmer, 2011: Gender differences in smoking and smoking cessation treatment: an examination of the organizational features related to care^279^ | Smoking cessation | 15033 | Quality | Patient-reported receipt of smoking cessation treatments | No | 2
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Utilization | Mental health utilization (outpatient, inpatient, residential) | Mixed/Unclear | 2
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Health Outcome | GAF, self-reported mental health (BASIS-24) | No | 2
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Utilization | Retention in VA care | No | 3
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Health Outcome | 5-year survival | No | 3
Fontana, 2010: Female Veterans of Iraq and Afghanistan seeking care from VA specialized PTSD programs: Comparison with male Veterans and female war zone Veterans of previous eras^281^ | Mental health (PTSD) | 11256 | Quality | Psychiatric disability and medical disability | Mixed/Unclear | 2
Fontana, 2010: Female Veterans of Iraq and Afghanistan seeking care from VA specialized PTSD programs: Comparison with male Veterans and female war zone Veterans of previous eras^281^ | Mental health (PTSD) | 11256 | Health Outcome | Diagnosis of PTSD, alcohol abuse/depression, drug abuse/depression, anxiety disorder, mood disorder, bipolar disorder, schizophrenia, medical problem; service connection for PTSD, other psychiatric disorder, or medical disorder | Mixed/Unclear | 2
Frayne, 2006: Health status among 28,000 women Veterans. The VA Women's Health Program Evaluation Project^282^ | Mental health | 679859 | Health Outcome | Physical health survey | No | 3
Frayne, 2007: Gender and use of care: planning for tomorrow's Veterans Health Administration^283^ | Women's health, utilization | 4122381 | Utilization | Inpatient and outpatient utilization | Mixed/Unclear | 3
Freedy, 2010: Gender differences in traumatic event exposure and mental health among Veteran primary care patients^284^ | Mental health | 865 | Health Outcome | Mental health diagnoses | Mixed/Unclear | 0
Garfield, 2011: Factors associated with receipt of adequate antidepressant pharmacotherapy by VA patients with recurrent depression^285^ | Mental health (Depression) | 26770 | Quality | Receipt of some antidepressant therapy, adequate acute-phase pharmacotherapy, and adequate continuation-phase pharmacotherapy | No | 2
Gellad, 2011: Longitudinal adherence to fecal occult blood testing impacts colorectal cancer screening quality^286^ | Cancer (colorectal) | 1112645 | Quality | Colorectal cancer screening | No | 2
Goldstein, 2014: Heart matters: Gender and racial differences cardiovascular disease risk factor control among Veterans^132^ | Cardiovascular disease | 24965 | Quality | Measures of blood pressure, LDL-C values, hemoglobin A1c levels | Mixed/Unclear | 2
Griffin, 2009: Are gender differences in colorectal cancer screening rates due to differences in self-reporting?^287^ | Cancer (colorectal) | 345 | Quality | Colorectal cancer screening | No | 0
Grubaugh, 2009: Equity in Veterans Affairs disability claims adjudication in a national sample of Veterans^139^ | Disability | 20048 | Quality | Disability benefits | Mixed/Unclear | 2
Harris, 2010: Associations between AUDIT-C and mortality vary by age and sex^288^ | Mental health (serious mental illness) | 225092 | Health Outcome | 2-year mortality risk | Yes | 3
Haskell, 2009: Pain among Veterans of Operations Enduring Freedom and Iraqi Freedom: Do women and men differ?^142^ | Pain | 153212 | Health Outcome | Pain: reported any pain, reported moderate-severe pain, reported persistent pain | Mixed/Unclear | 3
Haskell, 2010: Gender differences in rates of depression, PTSD, pain, obesity, and military sexual trauma among Connecticut War Veterans of Iraq and Afghanistan^289^ | Mental health (Depression, PTSD), pain | 1229 | Health Outcome | Mental health diagnosis | Mixed/Unclear | 1
Haskell, 2011: The burden of illness in the first year home: Do male and female VA users differ in health conditions and healthcare utilization^290^ | General health | 163812 | Utilization | Utilization | Mixed/Unclear | 2
Haskell, 2012: Prevalence of painful musculoskeletal conditions in female and male Veterans in 7 years after return from deployment in Operation Enduring Freedom/Operation Iraqi Freedom^7^ | Pain (back problems, musculoskeletal conditions and joint disorders) | 450329 | Health Outcome | Prevalence of back problems, musculoskeletal conditions, and joint disorders | Yes | 3
Haskell, 2014: Sex differences in patient and provider response to elevated low-density lipoprotein cholesterol^291^ | Cardiovascular (lipid management) | 41763 | Quality | Ordering or adjusting of medication with elevated LDL | Yes | 2
Hausmann, 2014: Patterns of sex and racial/ethnic differences in patient health care experiences in US Veterans Affairs hospitals^147^ | General health | 50471 | Quality | Patient reports of positive and negative healthcare experiences at VA facilities | Mixed/Unclear | 2
Hawkins, 2010: Recognition and management of alcohol misuse in OEF/OIF and other Veterans in the VA: a cross-sectional study^292^ | Mental health (substance use disorder) | 12092 | Health Outcome | Alcohol misuse screening | No | 2
Hawkins, 2012: Prevalence, predictors, and service utilization of patients with recurrent use of Veterans Affairs substance use disorder specialty care^293^ | Mental health (substance use disorder) | 1640 | Utilization | Utilization of substance use disorder specialty services following an index encounter | No | 0
Heidenreich, 2009: Disparities in VA heart failure care^148^ | Cardiovascular (heart failure) | NR -likely large | Quality | Guideline concordant heart failure care | Yes | 2
Higgins, 2014: Persistent pain and comorbidity among Operation Enduring Freedom/Operation Iraqi Freedom/Operation New Dawn Veterans^149^ | Pain (chronic) | 5242 | Health Outcome | Persistent pain (either self-rated scale, ICD-9 pain diagnosis, pain clinic visit, or opioid prescription) | Yes | 1
Hoffmire, 2015: Changes in suicide mortality for Veterans and non-Veterans by gender and history of VHA service use, 2000-2010^294^ | Mental health | 173969 | Health Outcome | Suicide rates (Standardized Mortality Ratio) | Yes | 3
Hundt, 2014: Predisposing, enabling, and need factors as predictors of low and high psychotherapy utilization in Veterans^295^ | Mental health, Utilization | 130331 | Utilization | Psychotherapy utilization | Mixed/Unclear | 3
Ilgen, 2009: Exploratory data mining analysis identifying subgroups of patients with depression who are at high risk for suicide^157^ | Mental health (Depression) | 887869 | Health Outcome | Suicide | No | 2
Ilgen, 2010: Psychiatric diagnoses and risk of suicide in Veterans^296^ | Mental health (multiple) | 3291891 | Health Outcome | Suicide | No | 3
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/rehospitalization | No | 1
Iverson, 2011: Psychiatric diagnoses and neurobehavioral symptom severity among OEF/OIF VA patients with deployment-related traumatic brain injury: a gender comparison^297^ | Mental health (multiple), TBI | 12605 | Health Outcome | Mental health diagnoses | Mixed/Unclear | 2
Kales, 2010: Who receives outpatient monitoring during high-risk depression treatment periods?^162^ | Mental health (Depression) | 494673 | Utilization | Number of outpatient visits following mental health hospitalization or outpatient initiation of antidepressant medication | No | 3
Kaur, 2007: Gender differences in health care utilization among Veterans with chronic pain^298^ | Pain (chronic) | 1218 | Utilization | Number of clinic visits | Mixed/Unclear | 0
Kilbourne, 2006: Quality of care for substance use disorders in patients with serious mental illness^167^ | Mental health (substance use disorder) | 8083 | Quality | Identification of substance use disorders, initiation of treatment, engagement in treatment | Mixed/Unclear | 1
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Quality | Receipt of HCV testing, notified ≤60 days | Mixed/Unclear | 2
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Health Outcome | HCV positive | No | 2
Kimerling, 2011: Military sexual trauma and patient perceptions of Veteran Health Administration health care quality^170^ | Mental health (sexual trauma) | 164632 | Quality | Patient satisfaction with VHA outpatient care | Mixed/Unclear | 2
Leslie, 2011: VA health care utilization and costs among male and female Veterans in the year after service in Afghanistan and Iraq^299^ | Utilization | 406463 | Utilization | Utilization, service-connected disability | Mixed/Unclear | 3
Lund, 2013: Patient and Facility Characteristics Associated with Benzodiazepine Prescribing for Veterans with PTSD^300^ | Mental health (PTSD) | 495309 | Quality | Benzodiazepine prescription | Yes | 3
Lynch, 2015: Geographic and racial/ethnic variations in patterns of multimorbidity burden in patients with type 2 diabetes^185^ | Diabetes | 892223 | Health Outcome | Multimorbidity | Mixed/Unclear | 3
Maguen, 2010: Gender differences in mental health diagnoses among Iraq and Afghanistan Veterans enrolled in Veterans affairs health care^301^ | Mental health (multiple) | 329049 | Health Outcome | Mental health diagnoses (depression, PTSD, substance use, adjustment disorder, anxiety, alcohol use disorder, eating disorders) | Mixed/Unclear | 2
Montgomery, 2014: Services utilization among recently homeless Veterans: a gender-based comparison^302^ | Utilization | 584 | Utilization | Utilization: inpatient, outpatient, ED | Mixed/Unclear | 1
Phillips, 2015: Racial/ethnic disparities in monitoring metabolic parameters for patients with schizophrenia receiving antipsychotic medications^200^ | Mental health (serious mental illness) | 30258 | Quality | Monitoring of metabolic dysregulation | No | 1
Pugh, 2006: Assessing potentially inappropriate prescribing in the elderly Veterans Affairs population using the HEDIS 2006 quality measure^205^ | Geriatrics, Prescribing | 1096361 | Quality | Potentially inappropriate prescribing based on HEDIS criteria | Yes | 3
Pugh, 2008: Potentially inappropriate prescribing for the elderly: effects of geriatric care at the patient and health care system level^206^ | Geriatrics, Prescribing | 850154 | Quality | Potentially inappropriate prescribing in the elderly | Yes | 3
Pugh, 2011: Trends in use of high-risk medications for older Veterans: 2004 to 2006^207^ | Geriatrics, Prescribing | 1567467 | Quality | Use of high-risk medications for the elderly (HRME) | Yes | 3
Rogers, 2014: Healthcare utilization following mild traumatic brain injury in female Veterans^212^ | TBI | 12144 | Utilization | Utilization | Mixed/Unclear | 2
Runnals, 2013: Self-reported pain complaints among Afghanistan/Iraq era men and women Veterans with comorbid posttraumatic stress disorder and major depressive disorder^303^ | Pain, Mental health (PTSD, MDD) | 1614 | Health Outcome | Pain: back, muscle, and headaches | Yes | 0
Sajatovic, 2006: Self-reported medication treatment adherence among Veterans with bipolar disorder^304^ | Mental health (Bipolar) | 184 | Quality | Self-report of medication adherence | No | 1
Sajatovic, 2007: Treatment adherence with lithium and anticonvulsant medications among patients with bipolar disorder^217^ | Mental health (Bipolar) | 44637 | Quality | Adherence | No | 1
Sambamoorthi, 2012: Decomposing gender differences in low-density lipoprotein cholesterol among Veterans with or at risk for cardiovascular illness^219^ | Cardiovascular (lipid management) | 527568 | Quality | LDL-C greater than or equal to 130 | Yes | 3
Sayer, 2014: Gender differences in VA disability status for PTSD over time^305^ | Mental health (PTSD) | 2998 | Quality | Gain or loss of PTSD disability status over a 10-year period | No | 1
Schwartz, 2015: Gender differences in antipsychotics prescribed to Veterans with serious mental illness^306^ | Mental health (serious mental illness) | 4510 | Quality | Likelihood of incident prescription of APMs with low versus medium/high metabolic risk, adjusting for fiscal year of prescribing and selected Veteran demographic, mental health and physical health characteristics | No | 1
Seal, 2011: Substance use disorders in Iraq and Afghanistan Veterans in VA healthcare, 2001-2010: Implications for screening, diagnosis and treatment^226^ | Mental health (substance use disorder) | 456502 | Health Outcome | Presence or absence of substance use disorders (alcohol or drug use disorder) | No | 3
Seng, 2013: Prescription headache medication in OEF/OIF Veterans: results from the Women Veterans Cohort Study^307^ | Pain (Headache) | 551 | Quality | Taking prescription medication for headache | Mixed/Unclear | 0
Seyfried, 2011: Predictors of suicide in patients with dementia^308^ | Dementia | 294952 | Health Outcome | Suicide | No | 3
Singh, 2007: Effect of health-related quality of life on women and men's Veterans Affairs (VA) health care utilization and mortality^309^ | Utilization (inpatient, outpatient) | 36500 | Utilization | Inpatient and outpatient utilization | No | 2
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | No | 1
Street, 2013: Gender differences among Veterans deployed in support of the wars in Afghanistan and Iraq^310^ | Mental health (multiple) | 2344 | Health Outcome | Mental health conditions | Mixed/Unclear | 1
Taber, 2016: Overall graft loss versus death-censored graft loss: unmasking the magnitude of racial disparities in outcomes among US kidney transplant recipients^232^ | Renal | 4918 | Health Outcome | Overall graft loss, death and death-censored graft loss | No | 1
Teh, 2008: Gender differences in health-related quality of life for Veterans with serious mental illness^311^ | Mental health (serious mental illness) | 18017 | Health Outcome | Health-related quality of life – measured via SF-36 (mental health status, physical health status, activities of daily living), global health status question, question on ADL limitations, health interfered with social activities, and extent of bodily pain | Mixed/Unclear | 2
Tiwari, 2008: Guideline-consistent antidepressant treatment patterns among Veterans with diabetes and major depressive disorder^233^ | Mental health (Depression), Diabetes | 3953 | Quality | Proportion who have guideline-consistent antidepressant treatment | No | 1
Tsai, 2014: National comparison of literally homeless male and female VA service users: entry characteristics, clinical needs, and service patterns^312^ | Chronic Medical conditions and mental health | 119947 | Health Outcome | Rating of physical health, chronic medical conditions | Mixed/Unclear | 3
Tseng, 2006: Are there gender differences in diabetes care among elderly Medicare enrolled Veterans?^313^ | Diabetes | 235147 | Quality | Hemoglobin A1c, LDL-C values, and eye exams; intermediate outcomes were hemoglobin A1c and LDL-C values below recommended thresholds | Mixed/Unclear | 3
Tseng, 2006: Diabetes care among Veteran women with disability^236^ | Diabetes | 76874 | Quality | Hemoglobin A1c and LDL-C screening and control | Mixed/Unclear | 2
Tseng, 2007: The association between mental health functioning and nontraumatic lower extremity amputations in Veterans with diabetes^237^ | Diabetes | 114890 | Health Outcome | Major and minor non-traumatic lower extremity amputations | No | 3
Vimalananda, 2011: Gender disparities in lipid-lowering therapy among Veterans with diabetes^314^ | Diabetes | 111906 | Quality | Lipid Lowering Therapy | Yes | 3
Vimalananda, 2013: Accounting for clinical action reduces estimates of gender disparities in lipid management for diabetic Veterans^315^ | Diabetes | 668209 | Quality | Quality outcomes: low density lipoprotein (LDL-C) levels and clinical action for lipid management | Yes | 3
Vimalananda, 2013: Cardiovascular disease risk factors among women Veterans at VA medical facilities^240^ | Cardiovascular disease | 2527496 | Quality | Hypertension, hyperlipidemia, obesity | No | 2
Vimalananda, 2013: Cardiovascular disease risk factors among women Veterans at VA medical facilities^240^ | Cardiovascular disease | 2527496 | Health Outcome | Diabetes diagnosis | No | 2
Virani, 2011: Frequency and correlates of treatment intensification for elevated cholesterol levels in patients with cardiovascular disease^316^ | Cardiovascular disease | 22888 | Quality | Intensification of lipid lowering | Yes | 2
Virani, 2015: Gender disparities in evidence-based statin therapy in patients with cardiovascular disease^317^ | Cardiovascular (Ischemic heart disease) | 972532 | Quality | Any statin prescription, high-intensity statin prescription | Yes | 2
Vogt, 2011: Gender differences in combat-related stressors and their association with postdeployment mental health in a nationally representative sample of US OEF/OIF Veterans^318^ | Mental health (multiple) | 592 | Health Outcome | Mental health (PTSD symptomatology, depression, mental health functioning, substance abuse) | No | 0
Weimer, 2013: Sex differences in the medical care of VA patients with chronic non-cancer pain^319^ | Pain (chronic pain) | 17583 | Utilization | ED visits for pain-related complaint, primary care utilization | Mixed/Unclear | 2
Weimer, 2013: Sex differences in the medical care of VA patients with chronic non-cancer pain^319^ | Pain (chronic pain) | 17583 | Quality | Prescribed chronic opioid therapy, prescribed benzodiazepine therapy, receiving physical therapy, receiving urine drug testing | Mixed/Unclear | 2
Weimer, 2013: Sex differences in the medical care of VA patients with chronic non-cancer pain^319^ | Pain (chronic pain) | 17583 | Health Outcome | Diagnosis of 2 or more pain conditions | Yes | 2
Westermeyer, 2009: A comparison of substance use disorder severity and course in American Indian male and female Veterans^320^ | Mental health | 362 | Utilization | Mental healthcare utilization | Mixed/Unclear | 1
Westermeyer, 2009: A comparison of substance use disorder severity and course in American Indian male and female Veterans^320^ | Mental health | 362 | Health Outcome | Mental health diagnoses | No | 1
Wheeler, 2009: Women Veterans and outcomes after acute myocardial infarction^321^ | Cardiovascular disease | 13495 | Quality | HF outcomes | No | 2
Wheeler, 2009: Women Veterans and outcomes after acute myocardial infarction^321^ | Cardiovascular disease | 13495 | Health Outcome | HF outcomes | No | 2
Whitehead, 2014: Improving trends in gender disparities in the Department of Veterans Affairs: 2008–2013^8^ | Women's health | Ranges by outcome: 1820 to 107,659 | Quality | Gender differences by year in % screened for depression, PTSD, cholesterol management for patients with DM and IHD | Mixed/Unclear | 2
Women Veterans Health Strategic Health Care Group, 2012: Gender Differences in Performance Measures, VHA 2008-2011^11^ | Preventive and ambulatory care | NR, but national VA data | Quality | Clinical quality performance measures | Mixed/Unclear | 2
Wright, 2006: Patient satisfaction of female and male users of Veterans Health Administration services^322^ | General health | 74662 | Quality | Self-rated quality of care | Mixed/Unclear | 2
Wright, 2012: Comparing the Care of Men and Women Veterans in the Department of Veterans Affairs^323^ | General health | 238272 | Quality | Key patient-centered care measures, satisfaction with and perception of care | No | 3
Zeber, 2007: Self-reported access to general medical and psychiatric care among Veterans with bipolar disorder^249^ | Mental health (Bipolar) | 435 | Utilization | Patient perception of access to health and mental health | No | 0
Zinzow, 2008: Sexual assault, mental health, and service use among male and female Veterans seen in Veterans Affairs primary care clinics: a multi-site study^324^ | Mental health, Utilization | 816 | Utilization | Overall utilization | No | 0