# APPENDIX I HEALTH DISPARITIES BY RACE/ETHNICITY – NATIVE HAWAIIAN/PACIFIC ISLANDER

Evidence Map Health Disparities in Veterans by Race/Ethnicity – Native Hawaiian/Pacific Islander

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans by Race/Ethnicity – Native Hawaiian/Pacific Islander

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 3630420 | Quality | HCV screening rates | No | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 3630420 | Health Outcomes | HCV prevalence | No | 2
Mackenzie, 2010: Impact of rural residence on survival of male Veterans affairs patients after age 65^186^ | Mortality (65+) | 372463 | Health Outcomes | Mortality | No | 3
Shaw, 2014: Posttraumatic stress disorder and risk of spontaneous preterm birth^227^ | Women's health (preterm birth), Mental health (PTSD) | 16334 | Health Outcomes | Spontaneous preterm birth | No | 2
Spoont, 2009: Race and ethnicity as factors in mental health service use among Veterans with PTSD^230^ | Mental health (PTSD) | 20284 | Utilization | Mental health care receipt (psychotropic prescription, AD prescription, counseling) | No | 2
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | No | 2