# APPENDIX H HEALTH DISPARITIES BY RACE/ETHNICITY – ASIAN/PACIFIC ISLANDER

Evidence Map Health Disparities in Veterans by Race/Ethnicity – Asian/Pacific Islander

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans by Race/Ethnicity – Asian/Pacific Islander

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 3638179 | Quality | HCV screening rates | No | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 3638179 | Health Outcome | HCV prevalence | No | 2
Boehmer, 2016: Dental care in an equal access system valuing equity: Are there racial disparities?^83^ | Dental | 71315 | Quality | Receipt of root canal vs extraction | No | 1
Cone, 2011: [underlined: Demographic determinants of response to statin medications]^101^ | Cardiovascular (coronary artery disease) | 5191 | Quality | Achieving goal of LDL-C <100 | No | 0
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Health Outcome | 5-year survival | No | 2
Ganti, 2014: Association between race and survival of patients with non-small-cell lung cancer in the United States Veteran Affairs population^127^ | Cancer | 82414 | Health Outcome | Mortality | No | 1
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/rehospitalization | No | 1
Kazerooni, 2014: Predictors of adherence to hormonal contraceptives in a female Veteran population^165^ | Women's health (hormonal contraceptives) | 805 | Health Outcome | Adherence to hormonal contraceptive medication (medication possession ratio >.9) | No | 0
Koo, 2015: Race-ethnicity and gender differences in VA health care service utilization among US Veterans of recent conflicts^172^ | Preventive and ambulatory care | 309050 | Utilization | Healthcare utilization | No | 3
Mackenzie, 2010: Impact of rural residence on survival of male Veterans affairs patients after age 65^186^ | Mortality (65+) | 372463 | Health Outcome | Mortality | No | 3
Quinones, 2014: Racial and ethnic differences in receipt of antidepressants and psychotherapy by Veterans with chronic depression^208^ | Mental health (depression) | 62095 | Quality | Adequate depression care | Mixed/Unclear | 2
Sajatovic, 2007: Treatment adherence with lithium and anticonvulsant medications among patients with bipolar disorder^217^ | Mental health (bipolar) | 44637 | Quality | Adherence | Mixed/Unclear | 1
Shaw, 2014: Posttraumatic stress disorder and risk of spontaneous preterm birth^227^ | Women's health (preterm birth), Mental health (PTSD) | 16334 | Health Outcome | Spontaneous preterm birth | No | 2
Shimada, 2008: Advances in patient safety: racial disparities in Patient Safety Indicator (PSI) rates in the Veterans Health Administration^228^ | Inpatient care | 1032103 | Quality | Patient safety indicators | No | 2
Shimada, 2008: Racial disparities in patient safety indicator (PSI) rates in the Veterans Health Administration^229^ | Surgery (postoperative and surgical complications) | 1032103 | Health Outcome | Death in low-mortality Diagnosis-Related Groups (DRG) | No | 3
Spoont, 2009: Race and ethnicity as factors in mental health service use among Veterans with PTSD^230^ | Mental health (PTSD) | 20284 | Utilization | Mental health care receipt (psychotropic prescription, AD prescription, counseling) | No | 2
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | No | 2
Tsai, 2014: Asian American and Pacific Islander military Veterans in the United States: health service use and perceived barriers to mental health services^262^ | Mental health (perceived barriers) | 8315 | Utilization | Inpatient or outpatient mental health services use | No | 1
Tsai, 2014: Asian American and Pacific Islander military Veterans in the United States: health service use and perceived barriers to mental health services^262^ | Mental health (perceived barriers) | 8315 | Quality | SF-12 mental health scores | No | 0
Tsai, 2014: Asian American and Pacific Islander military Veterans in the United States: health service use and perceived barriers to mental health services^262^ | Mental health (perceived barriers) | 8315 | Health Outcome | Reported need for mental health or medical services | No | 1
Tsai, 2014: The effects of race and other socioeconomic factors on health service use among American military Veterans^235^ | Preventive and ambulatory care | 19270 | Utilization | Health service use | No | 2