# APPENDIX G HEALTH DISPARITIES BY RACE/ETHNICITY – AMERICAN INDIAN/ALASKA NATIVE

Evidence Map Health Disparities in Veterans by Race/Ethnicity – American Indian/Alaska Native

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans by Race/Ethnicity – American Indian/Alaska Native

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Alvord, 2009: Surgical outcomes in American Indian Veterans: a closer look^259^ | Surgery/Postoperative complications | 4419 | Health Outcome | Post-operative complications, mortality | No | 1
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 823383 | Quality | Proportion screened for HCV | No | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 823383 | Health Outcome | HCV infection prevalence | Yes | 2
Cone, 2011: Demographic determinants of response to statin medications^101^ | Cardiovascular (coronary artery disease) | 5191 | Quality | Achieving goal of LDL-C <100 | Yes | 0
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Health Outcome | 5-year survival | No | 2
Ganti, 2014: Association between race and survival of patients with non-small-cell lung cancer in the United States Veteran Affairs population^127^ | Cancer (non-small cell lung carcinoma) | 82414 | Health Outcome | Mortality | No | 1
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/rehospitalization | No | 1
Johnson, 2010: Healthcare disparities for American Indian Veterans in the United States: a population-based study^260^ | General health | 34504 | Quality | Delaying care, restricted access to care due to financial concerns | Yes | 2
Kaufman, 2013: Rural native Veterans in the Veterans Health Administration: characteristics and service utilization patterns^261^ | General health | 287675 | Quality | Number of diagnoses | Yes | 2
Kaufman, 2013: Rural native Veterans in the Veterans Health Administration: characteristics and service utilization patterns^261^ | General health | 287675 | Health Outcome | Service connection disability | No | 2
Kazerooni, 2014: Predictors of adherence to hormonal contraceptives in a female Veteran population^165^ | Women's health (hormonal contraceptives) | 805 | Health Outcome | Adherence to hormonal contraceptive medication (medication possession ratio >.9) | No | 0
Koo, 2015: Race-ethnicity and gender differences in VA health care service utilization among US Veterans of recent conflicts^172^ | Utilization | 309050 | Utilization | Healthcare utilization | Mixed/Unclear | 3
Landrum, 2012: Race and income association with health service utilization for Veterans with heart failure^179^ | Cardiovascular (heart failure) | 149 | Utilization | Heart failure-related outcomes (30-day, 90-day, 1-year and total readmissions, ED visits, and total bed days of care) | No | 0
Luncheon, 2012: Health-related quality of life among US Veterans and civilians by race and ethnicity^183^ | Quality of life, health-related | 110000 | Health Outcome | Physically unhealthy days, mentally unhealthy days, recent activity limitation days | Mixed/Unclear | 3
Mackenzie, 2010: Impact of rural residence on survival of male Veterans affairs patients after age 65^186^ | Mortality (65+) | 372463 | Health Outcome | Mortality | No | 3
Quinones, 2014: Racial and ethnic differences in receipt of antidepressants and psychotherapy by Veterans with chronic depression^208^ | Mental health (Depression) | 62095 | Quality | Adequate depression care | Mixed/Unclear | 2
Sajatovic, 2007: Treatment adherence with lithium and anticonvulsant medications among patients with bipolar disorder^217^ | Mental health (Bipolar) | 44637 | Quality | Adherence | No | 1
Shaw, 2014: Posttraumatic stress disorder and risk of spontaneous preterm birth^227^ | Mental health (PTSD), Childbirth | 16334 | Health Outcome | Spontaneous preterm birth | Yes | 2
Shimada, 2008: Advances in patient safety: racial disparities in Patient Safety Indicator (PSI) rates in the Veterans Health Administration^228^ | Inpatient care | 1032103 | Quality | Patient safety indicators | No | 2
Shimada, 2008: Racial disparities in patient safety indicator (PSI) rates in the Veterans Health Administration^229^ | Surgery (postoperative and surgical complications) | 1032103 | Health Outcome | Death in low-mortality Diagnosis-Related Groups (DRG) | No | 3
Spoont, 2009: Race and ethnicity as factors in mental health service use among Veterans with PTSD^230^ | Mental health (PTSD) | 20284 | Utilization | Mental health care receipt (psychotropic prescription, AD prescription, counseling) | Mixed/Unclear | 2
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | No | 2
Tsai, 2014: The effects of race and other socioeconomic factors on health service use among American military Veterans^235^ | Utilization | 19270 | Utilization | Health service use | No | 2