# APPENDIX F HEALTH DISPARITIES BY RACE/ETHNICITY – HISPANIC/LATINO

Evidence Map Health Disparities in Veterans by Race/Ethnicity – Hispanic/Latino

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans by Race/Ethnicity – Hispanic/Latino

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Axon, 2011: Racial and ethnic differences in longitudinal blood pressure control in Veterans with type 2 diabetes mellitus^75^ | Diabetes | 5319 | Quality | Proportion of patients with controlled blood pressure | Yes | 0
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 3907136 | Quality | HCV screening rates | No | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 3907136 | Health Outcomes | HCV prevalence | Yes | 2
Banerjea, 2007: Chronic illness with complexities: Mental illness and substance use among Veteran clinic users with diabetes^78^ | Diabetes, co-occurring substance use and mental health disorders in patients with diabetes | 485893 | Health Outcomes | Mental health status, substance use disorder, combined mental health and substance use disorder, access to care, and diabetes-related health complications | Mixed/Unclear | 3
Banerjea, 2009: Mental illness and substance use disorders among women Veterans with diabetes^79^ | Mental health (Substance Use Disorder), diabetes | 14984 | Health Outcomes | Serious mental illness and/or substance use disorder diagnoses | No | 2
Bierman, 2007: Sex differences in inappropriate prescribing among elderly Veterans^82^ | Geriatrics, Prescribing | 965756 | Quality | Zhan criteria for inappropriate prescribing for older adults | Yes | 3
Boehmer, 2016: Dental care in an equal access system valuing equity: are there racial disparities?^83^ | Dental | 71315 | Quality | Receipt of root canal vs extraction | Mixed/Unclear | 1
Borrero, 2012: Contraceptive care in the VA health care system^84^ | Women's health (contraceptive care) | 103950 | Quality | Receipt and type of contraception | Mixed/Unclear | 3
Borrero, 2013: Adherence to hormonal contraception among women Veterans: differences by race/ethnicity and contraceptive supply^85^ | Women's health (hormonal contraceptives) | 6946 | Health Outcomes | Adherence to hormonal contraceptive medication (time between refills, total months of contraceptive coverage, whether the woman had contraceptive coverage during the last week of FY 2008) | Yes | 1
Braun, 2008: Racial and ethnic differences in the treatment of seriously ill patients: a comparison of African-American, Caucasian and Hispanic Veterans^86^ | Inpatient/acute care, elderly | 166059 | Quality | Use of life-sustaining treatment (Resuscitation, Mechanical Ventilation, Intensive Care Unit, Enteral Nutrition, Transfusion) | Mixed/Unclear | 3
Butt, 2006: Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects^93^ | HCV, HIV | 6502 | Quality | Prescribed treatment for HCV | Yes | 1
C'De Baca, 2014: Ethnic differences in personality disorder patterns among women Veterans diagnosed with PTSD^95^ | Mental health (Personality Disorders) | 260 | Health Outcomes | Personality disorder diagnosis | No | 0
Cone, 2011: Demographic determinants of response to statin medications^101^ | Cardiovascular (coronary artery disease) | 5191 | Quality | Achieving goal of LDL-C <100 | No | 0
Copeland, 2011: Ethnicity and race variations in receipt of surgery among Veterans with and without depression^103^ | Surgery | 309068 | Quality | Surgery | Mixed/Unclear | 3
Copeland, 2014: Prevalence of suicidality among Hispanic and African American Veterans following surgery^104^ | Mental health (SBI), surgery (organ, bone or joint, cancers, vascular, and amputations) | 89995 | Health Outcomes | Diagnosis of suicidal behavior or ideation | No | 2
Daskivich, 2015: Racial parity in tumor burden, treatment choice and survival outcomes in men with prostate cancer in the VA healthcare system^107^ | Cancer (prostate) | 1258 | Quality | Tumor risk, Gleason score, clinical stage, aggressive treatment for low-, intermediate-, and high-risk disease | Mixed/Unclear | 1
Daskivich, 2015: Racial parity in tumor burden, treatment choice and survival outcomes in men with prostate cancer in the VA healthcare system^107^ | Cancer (prostate) | 1258 | Health Outcomes | Cancer-related mortality, all-cause mortality | No | 1
Dismuke, 2016: Racial/ethnic disparities in VA services utilization as a partial pathway to mortality differentials among Veterans diagnosed with TBI^109^ | TBI | 14960 | Utilization | Total visits | Mixed/Unclear | 2
Dismuke, 2016: Racial/ethnic disparities in VA services utilization as a partial pathway to mortality differentials among Veterans diagnosed with TBI^109^ | TBI | 14960 | Health Outcomes | Mortality | No | 2
Dobscha, 2009: Associations between race and ethnicity and treatment for chronic pain in the VA110 | Pain (chronic) | 9121 women 246,401 men | Utilization | Question on receipt of treatment for chronic pain in past year, question on effectiveness of chronic pain care | Mixed/Unclear | 3
Duffy, 2012: Risk of smoking and receipt of cessation services among Veterans with mental disorders^111^ | Smoking cessation | 224193 | Quality | Physician advised quitting, physician recommended medication, physician discussed quitting methods | Yes | 3
Egede, 2011: Longitudinal ethnic differences in multiple cardiovascular risk factor control in a cohort of US adults with diabetes^113^ | Cardiovascular disease, Diabetes | 11203 | Quality | CV risk factor control (glycemic, BP, LDL-C) | Yes | 1
Egede, 2011: Regional, geographic, and ethnic differences in medication adherence among adults with type 2 diabetes^114^ | Diabetes | 690968 | Quality | Medication adherence (MPR-med possession ratio) | Yes | 3
Egede, 2011: Regional, geographic, and racial/ethnic variation in glycemic control in a national sample of Veterans with diabetes^115^ | Diabetes | 690698 | Quality | Hemoglobin A1c level, poor control of hemoglobin A1c (<80%) | Yes | 3
Egede, 2012: Racial/ethnic disparities in mortality risk among US Veterans with traumatic brain injury^116^ | TBI | 14690 | Health Outcomes | Mortality | Yes | 2
Egede, 2013: Differential impact of longitudinal medication non-adherence on mortality by race/ethnicity among Veterans with diabetes^117^ | Diabetes | 629563 | Health Outcomes | Medication nonadherence-associated mortality | Yes | 3
El-Serag, 2014: Racial differences in the progression to cirrhosis and hepatocellular carcinoma in HCV-infected Veterans^121^ | HCV, cancer (liver) | 149407 | Health Outcomes | Risk of cirrhosis or hepatocellular cancer | Yes | 3
Fischer, 2007: Lack of ethnic differences in end-of-life care in the Veterans Health Administration^122^ | End-of-life care (palliative care) | 217 | Quality | Receipt of palliative care measures (advanced directive discussions, treatment of pain if present, symptom-directed plan, DNR orders) | No | 0
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Utilization | Retention in VA care | No | 3
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Health Outcomes | 5-year survival | No | 3
Garrido, 2014: Benzodiazepine and sedative-hypnotic use among older seriously Ill Veterans: choosing wisely?^128^ | Geriatrics, Prescribing | 222 | Quality | Potentially inappropriate use of benzodiazepines or other sedative-hypnotics (BSHs) | Yes | 0
Gerber, 2015: Hormone therapy use in women Veterans accessing Veterans Health Administration care: a national cross-sectional study^130^ | Women's health (hormone therapy) | 157195 | Quality | Rx of HT (hormone therapy) | No | 3
Halanych, 2006: Racial/ethnic differences in diabetes care for older Veterans: accounting for dual health system use changes conclusions^140^ | Diabetes, geriatrics | 5931 | Quality | Hemoglobin A1c, LDL-C screenings, eye exam | Mixed/Unclear | 1
Haskell, 2008: Determinants of hormone therapy discontinuation among female Veterans nationally^141^ | Women's health (hormone therapy) | 36222 | Quality | Hormone therapy discontinuation | No | 2
Haskell, 2009: Pain among Veterans of Operations Enduring Freedom and Iraqi Freedom: Do women and men differ?^142^ | Pain | 153212 | Health Outcomes | Pain: reported any pain, reported moderate-severe pain, reported persistent pain | No | 3
Hausmann, 2013: Understanding racial and ethnic differences in patient experiences with outpatient health care in Veterans Affairs Medical Centers^146^ | Preventive and ambulatory care | 211459 | Quality | Getting needed care, getting care quickly, how well doctors and nurses communicate, rating of personal doctor/nurse/specialist, overall healthcare rating, use of shared decision-making, pharmacy services | Mixed/Unclear | 3
Hausmann, 2014: Patterns of sex and racial/ethnic differences in patient health care experiences in US Veterans Affairs hospitals^147^ | General health | 50471 | Quality | Patient reports of positive and negative healthcare experiences at VA facilities | Mixed/Unclear | 2
Higgins, 2014: Persistent pain and comorbidity among Operation Enduring Freedom/Operation Iraqi Freedom/Operation New Dawn Veterans^149^ | Pain (chronic) | 5242 | Health Outcomes | Persistent pain (either self-rated scale, ICD-9 pain diagnosis, pain clinic visit, or opioid Rx) | No | 1
Hope, 2009: New-onset geriatric epilepsy care: race, setting of diagnosis, and choice of antiepileptic drug^150^ | Epilepsy | 9682 | Quality | Suboptimal antiepileptic drug (AED) prescribing | No | 1
Hunt, 2013: Impact of diabetes control on mortality by race in a national cohort of Veterans^155^ | Diabetes | 892223 | Health Outcomes | Mortality | Mixed/Unclear | 4
Ibrahim, 2008: Race, ethnicity and length of hospital stay after knee or hip arthroplasty^156^ | Pain (chronic) | 18,263 | Utilization | Length of hospital stay | No | 2
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcomes | Time to reinstitutionalization/rehospitalization | No | 1
Jackson, 2008: Racial/ethnic and educational-level differences in diabetes care experiences in primary care^258^ | Diabetes | 189 | Quality | Patient perceptions of alignment with chronic care model (Patient Assessment of Chronic Illness Care) | No | 1
Jia, 2010: Racial and ethnic disparities in post-stroke depression detection^160^ | Cardiovascular (Stroke) | 5825 | Health Outcomes | Diagnosis of post-stroke depression | No | 1
Kales, 2010: Who receives outpatient monitoring during high-risk depression treatment periods?^162^ | Mental health (Depression) | 494673 | Utilization | Number of outpatient visits following mental health hospitalization or outpatient initiation of antidepressant medication | No | 3
Kalkonde, 2009: Ethnic disparities in the treatment of dementia in Veterans^163^ | Dementia | 410 | Quality | Imaging, neuropsychological testing, and depression screening | Mixed/Unclear | 0
Kalkonde, 2009: Ethnic disparities in the treatment of dementia in Veterans^163^ | Dementia | 410 | Health Outcomes | Dementia diagnosis | No | 0
Kimerling, 2011: Military sexual trauma and patient perceptions of Veteran Health Administration health care quality^170^ | Mental health (sexual trauma) | 164632 | Quality | Patient satisfaction with VHA outpatient care | Yes | 3
Koo, 2015: Race-ethnicity and gender differences in VA health care service utilization among US Veterans of recent conflicts^172^ | Utilization | 309050 | Utilization | Healthcare utilization | Mixed/Unclear | 3
Luca, 2016: Mental health care utilization: how race, ethnicity and Veteran status are associated with seeking help^182^ | Mental health | 1124 | Utilization | Receipt of mental health treatment | No | 1
Luncheon, 2012: Health-related quality of life among US Veterans and civilians by race and ethnicity^183^ | Quality of life, health-related | 110000 | Health Outcomes | Physically unhealthy days, mentally unhealthy days, recent activity limitation days | No | 3
Lynch, 2015: Geographic and racial/ethnic variations in patterns of multimorbidity burden in patients with type 2 diabetes^185^ | Diabetes | 892223 | Health Outcomes | Multimorbidity | No | 3
Mackenzie, 2010: Impact of rural residence on survival of male Veterans affairs patients after age 65186 | Mortality (65+) | 372463 | Health Outcomes | Mortality | No | 3
Mattocks, 2015: Infertility care among OEF/OIF/OND women Veterans in the Department of Veterans Affairs^187^ | Women's health (Reproductive health) | 1323 | Quality | Received an infertility assessment | No | 0
Phillips, 2015: Racial/ethnic disparities in monitoring metabolic parameters for patients with schizophrenia receiving antipsychotic medications^200^ | Mental health (serious mental illness) | 30258 | Quality | Monitoring of metabolic dysregulation | Mixed/Unclear | 1
Poon, 2009: Racial/ethnic disparities in medication use among Veterans with hypertension and dementia: a national cohort study^204^ | Dementia, Cardiovascular (hypertension) | 56561 | Quality | Prevalence of each medication class and medication possession ratio (MPR)-medication adherence | Yes | 2
Pugh, 2006: Assessing potentially inappropriate prescribing in the elderly Veterans Affairs population using the HEDIS 2006 quality measure^205^ | Geriatrics, Prescribing | 1096361 | Quality | Potentially inappropriate prescribing based on HEDIS criteria | Yes | 3
Pugh, 2011: Trends in use of high-risk medications for older Veterans: 2004 to 2006^207^ | Geriatrics, Prescribing | 1567467 | Quality | Use of high risk medications for the elderly (HRME) | Yes | 3
Quinones, 2014: Racial and ethnic differences in receipt of antidepressants and psychotherapy by Veterans with chronic depression^208^ | Mental health (Depression) | 62095 | Quality | Adequate depression care | Mixed/Unclear | 2
Rose, 2013: Racial/ethnic differences in cardiovascular risk factors among women Veterans^213^ | Cardiovascular | 3611 | Health Outcomes | Cardiovascular disease risk factors | Mixed/Unclear | 1
Sajatovic, 2007: Treatment adherence with lithium and anticonvulsant medications among patients with bipolar disorder^217^ | Mental health (Bipolar) | 44637 | Quality | Adherence | Yes | 1
Sambamoorthi, 2012: Decomposing gender differences in low-density lipoprotein cholesterol among Veterans with or at risk for cardiovascular illness^219^ | Cardiovascular (lipid management) | 527568 | Quality | LDL-C greater than or equal to 130 | No | 3
Seal, 2011: Substance use disorders in Iraq and Afghanistan Veterans in VA healthcare, 2001-2010: Implications for screening, diagnosis and treatment^226^ | Mental health (substance use disorder) | 456502 | Health Outcomes | Presence or absence of substance use disorders (alcohol or drug use disorder) | No | 3
Shimada, 2008: Advances in patient safety: racial disparities in Patient Safety Indicator (PSI) rates in the Veterans Health Administration^228^ | Inpatient care | 1032103 | Quality | Multiple patient safety indicators | Mixed/Unclear | 2
Shimada, 2008: Racial disparities in patient safety indicator (PSI) rates in the Veterans Health Administration^229^ | Surgery (postoperative and surgical complications) | 1032103 | Health Outcomes | Death in low-mortality Diagnosis-Related Groups (DRG) | No | 3
Spoont, 2009: Race and ethnicity as factors in mental health service use among Veterans with PTSD^230^ | Mental health (PTSD) | 20284 | Utilization | Mental health care receipt (psychotropic prescription, AD prescription, counseling) | No | 2
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | Mixed/Unclear | 2
Tiwari, 2008: Guideline-consistent antidepressant treatment patterns among Veterans with diabetes and major depressive disorder^233^ | Mental health (Depression), diabetes | 3953 | Quality | Proportion who have guideline-consistent antidepressant treatment | No | 1
Tseng, 2006: Diabetes care among Veteran women with disability^236^ | Diabetes | 2344 | Quality | Hemoglobin A1c and LDL-C screening and control | Mixed/Unclear | 1
Tseng, 2011: Trends in initial lower extremity amputation rates among Veterans Health Administration health care System users from 2000 to 2004^238^ | Diabetes | 405,580 -739,377 | Health Outcomes | Lower extremity amputation | No | 3
Washington, 2009: Women Veterans ambulatory care use project, phase II^242^ | Women's health | 2174 | Utilization | Utilization of VA mental health care | Yes | 0
Washington, 2011: VA facility determinants of racial-ethnic variations in quality of care^243^ | Preventive and ambulatory care | NR - likely large | Quality | Colorectal cancer screening, receipt of immunizations, control of blood pressure, LDL-cholesterol, and diabetes | Yes | 5
Wendel, 2006: Racial and ethnic disparities in the control of cardiovascular disease risk factors in Southwest American Veterans with type 2 diabetes: the Diabetes Outcomes in Veterans Study^244^ | Cardiovascular, Diabetes | 338 | Quality | Glycemic control, insulin treatment intensity, lipid levels, and blood pressure control | Mixed/Unclear | 1
Zickmund, 2015: Racial and ethnic disparities in satisfaction with VA care^253^ | Utilization (satisfaction) | 1219 | Quality | Patient satisfaction (access, cost, pharmacy) | Mixed/Unclear | 1
Zivin, 2007: Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: Associations with patient and treatment setting characteristics^254^ | Mental health (depression) | 807694 | Health Outcomes | Suicide mortality | No | 3