# APPENDIX E HEALTH DISPARITIES BY RACE/ETHNICITY – AFRICAN AMERICAN/BLACK

Evidence Map Health Disparities in Veterans by Race/Ethnicity – African American/Black

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans by Race/Ethnicity – African American/Black

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Agarwal, 2008: Competing risk factor analysis of end-stage renal disease and mortality in chronic kidney disease^70^ | Renal disease | 220 | Health Outcome | End-stage renal disease, mortality | Mixed/Unclear | 1
Allott, 2014: Racial differences in adipose tissue distribution and risk of aggressive prostate cancer among men undergoing radiotherapy^71^ | Cancer (prostate) | 308 | Quality | Relationship between visceral obesity and prostate cancer | Yes | 0
Alston, 2014: Assistive technology and Veterans with severe disabilities: examining the relationships among race, personal factors, medical support, income support, and use^72^ | Disability | 16370 | Quality | Use of assistive technology by disabled Veterans | Yes | 2
Arora, 2012: The MDRD equation underestimates the prevalence of CKD among blacks and overestimates the prevalence of CKD among whites compared to the CKD-EPI equation: a retrospective cohort study^73^ | Renal | 97451 | Health Outcome | Mean estimated glomerular filtration rate at first serum creatinine | No | 3
Aujesky, 2007: African American race was associated with an increased risk of complications following venous thromboembolism^74^ | Venous thromboembolism | 168 | Quality | Processes of care, the time to administration of heparin after the diagnosis, and whether heparin therapy was initiated empirically before the diagnosis was objectively confirmed | No | 1
Aujesky, 2007: African American race was associated with an increased risk of complications following venous thromboembolism^74^ | Venous thromboembolism | 168 | Health Outcome | Mortality, recurrent venous thromboembolism, major bleeding | Yes | 1
Axon, 2011: Racial and ethnic differences in longitudinal blood pressure control in Veterans with type 2 diabetes mellitus^75^ | Diabetes | 5319 | Quality | Proportion of patients with controlled blood pressure | Yes | 0
Ayotte, 2010: Race differences in cardiac catheterization: the role of social contextual variables^76^ | Cardiovascular disease | 237 | Quality | Access to care | No | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 5500392 | Quality | HCV screening rates | Mixed/Unclear | 2
Backus, 2014: Impact of race/ethnicity and gender on HCV screening and prevalence among US Veterans in Department of Veterans Affairs care^77^ | HCV | 5500392 | Health Outcome | HCV prevalence | Yes | 2
Banerjea, 2007: Chronic illness with complexities: Mental illness and substance use among Veteran clinic users with diabetes^78^ | Diabetes, co-occurring substance use and mental health disorders in patients with diabetes | 485893 | Health Outcome | Mental health status, substance use disorder, combined mental health and substance use disorder, access to care, and diabetes-related health complications | Mixed/Unclear | 3
Banerjea, 2009: Mental illness and substance use disorders among women Veterans with diabetes^79^ | Mental health in women with diabetes | 14984 | Health Outcome | Serious mental illness and/or substance use disorder diagnoses | No | 2
Banez, 2009: Race and time from diagnosis to radical prostatectomy: does equal access mean equal timely access to the operating room?--Results from the SEARCH database^80^ | Cancer (prostate) | 1532 | Quality | Time between biopsy and radical prostatectomy | No | 1
Bean-Mayberry, 2009: Does sex influence immunization status for influenza and pneumonia in older Veterans^81^ | Preventive care (immunization status) | 48424 | Quality | Receipt of influenza immunization in the prior influenza season and receipt of pneumonia immunization ever | Yes | 2
Bierman, 2007: Sex differences in inappropriate prescribing among elderly Veterans^82^ | Geriatrics, prescribing | 965756 | Quality | Zhan criteria for inappropriate prescribing for older adults | No | 3
Boehmer, 2016: Dental care in an equal access system valuing equity: Are there racial disparities?^83^ | Dental | 71315 | Quality | Receipt of root canal versus extraction | Yes | 1
Borrero, 2012: Contraceptive care in the VA health care system^84^ | Women's health (contraceptive care) | 103950 | Quality | Receipt and type of contraception | Yes | 3
Borrero, 2013: Adherence to hormonal contraception among women Veterans: differences by race/ethnicity and contraceptive supply^85^ | Women's health (contraceptive care) | 6946 | Health Outcome | Adherence to hormonal contraceptive medication | No | 1
Braun, 2008: Racial and ethnic differences in the treatment of seriously ill patients: a comparison of African-American, Caucasian and Hispanic Veterans^86^ | Inpatient/acute care, elderly | 166059 | Quality | Use of life-sustaining treatment (resuscitation, mechanical ventilation, intensive care unit, enteral nutrition, transfusion) | Mixed/Unclear | 3
Bravata, 2008: Racial disparities in blood pressure management among stroke patients^87^ | Cardiovascular (stroke) | 287 | Quality | Blood pressure control | No | 0
Buchanan, 2014: The quality of care provided to patients with varices in the department of Veterans Affairs^88^ | Varices-related care | 550 | Quality | Rate of meeting specified quality indicators for varices-related care | No | 1
Burgess, 2011: Presence and correlates of racial disparities in adherence to colorectal cancer screening guidelines^89^ | Cancer (colorectal) | 2115 | Quality | Screening adherence | No | 1
Burgess, 2011: Presence and correlates of racial disparities in pain management^90^ | Pain | 261448 | Quality | Screening for pain | Yes | 3
Burgess, 2013: A national study of racial differences in pain screening rates in the VA health care system^91^ | Pain | 245504 | Quality | Pain screening | Yes | 3
Burgess, 2014: Racial differences in prescription of opioid analgesics for chronic noncancer pain in a national sample of Veterans^92^ | Pain (arthritis and pain management) | 99903 | Quality | Receipt of any opioid prescription | Mixed/Unclear | 2
Butt, 2006: Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects^93^ | HCV, HIV | 6502 | Quality | Prescribed treatment for HCV | Yes | 1
Cannon, 2009: Use of mechanical and noninvasive ventilation in black and white chronic obstructive pulmonary disease patients within the Veterans Administration health care system^94^ | Inpatient/acute care | 40498 | Quality | Use of mechanical ventilation and noninvasive ventilation | Mixed/Unclear | 2
C'De Baca, 2014: Ethnic differences in personality disorder patterns among women Veterans diagnosed with PTSD^95^ | Mental health (personality disorders) | 260 | Health Outcome | Personality Disorder diagnosis | Yes | 0
Cecere, 2012: Adherence to long-acting inhaled therapies among patients with chronic obstructive pulmonary disease (COPD)^96^ | Chronic obstructive pulmonary disease | 376 | Quality | Medication adherence | Yes | 2
Chapko, 2013: Hepatitis C antiviral treatment rates: Understanding racial disparities^97^ | HCV treatment | 118 | Quality | Decision to start antiviral treatment, likelihood of recommending imaging, patient satisfaction/concerns | Mixed/Unclear | 1
Cheng, 2012: Lower use of carotid artery imaging at minority-serving hospitals^98^ | Cardiovascular disease | 2162 | Quality | Receipt of carotid artery imaging 12 months prior and 2 months post-hospital admission for ischemic stroke | Mixed/Unclear | 1
Choi, 2007: Racial differences in end-stage renal disease rates in HIV infection versus diabetes^99^ | HIV | 2015891 | Health Outcome | Progression to end-stage renal disease | Yes | 3
Choi, 2009: White/black racial differences in risk of end-stage renal disease and death^100^ | Renal (end-stage renal disease) | 2015891 | Health Outcome | Progression to end-stage renal disease, time to death, rates of change in estimated glomerular filtration rate | Yes | 3
Cone, 2011: Demographic determinants of response to statin medications^101^ | Cardiovascular (coronary artery disease) | 5191 | Quality | Achieving goal of LDL-C <100 | No | 0
Copeland, 2008: Treatment adherence and illness insight in Veterans with bipolar disorder^102^ | Mental health | 435 | Quality | Medication adherence | Yes | 0
Copeland, 2011: Ethnicity and race variations in receipt of surgery among Veterans with and without depression^103^ | Surgery, mental health (depression) | 309068 | Quality | Surgery | Mixed/Unclear | 3
Copeland, 2014: Prevalence of suicidality among Hispanic and African American Veterans following surgery^104^ | Mental health, surgery (organ, bone or joint, cancers, vascular, and amputations) | 89995 | Health Outcome | Diagnosis of suicidal behavior or ideation | Yes | 2
Curran, 2009: Individual and program predictors of attrition from VA substance use treatment^105^ | Mental health (substance use disorder) | 8064 | Quality | Rates of attrition | No | 1
Dahodwala, 2011: Delayed Parkinson's disease diagnosis among African-Americans: the role of reporting of disability^106^ | Dementia, Parkinson's disease | 74 | Quality | Stage of Parkinson's disease at which patients presented for care | No | 0
Daskivich, 2015: Racial parity in tumor burden, treatment choice and survival outcomes in men with prostate cancer in the VA healthcare system^107^ | Cancer (prostate) | 1258 | Quality | Tumor risk, Gleason score, stage | No | 1
Daskivich, 2015: Racial parity in tumor burden, treatment choice and survival outcomes in men with prostate cancer in the VA healthcare system^107^ | Cancer (prostate) | 1258 | Health Outcome | Prostate cancer mortality | No | 1
Deswal, 2006: Racial variations in quality of care and outcomes in an ambulatory heart failure cohort^108^ | Cardiovascular (heart failure) | 18611 | Utilization | Heart failure-caused hospitalization | Yes | 2
Deswal, 2006: Racial variations in quality of care and outcomes in an ambulatory heart failure cohort^108^ | Cardiovascular (heart failure) | 18611 | Quality | Quality of care (documentation of left ventricular ejection fraction, appropriate prescription of angiotensin-converting enzyme inhibitors and beta-blockers, or if intolerant, angiotensin receptor blockers or hydralazine and nitrates among patients intolerant) | Mixed/Unclear | 2
Deswal, 2006: Racial variations in quality of care and outcomes in an ambulatory heart failure cohort^108^ | Cardiovascular (heart failure) | 18611 | Health Outcome | 1-year mortality | No | 2
Dismuke, 2016: Racial/ethnic disparities in VA services utilization as a partial pathway to mortality differentials among Veterans diagnosed with TBI^109^ | TBI | 14960 | Utilization | Number of rehabilitation, neurology, and TBI visits | No | 2
Dismuke, 2016: Racial/ethnic disparities in VA services utilization as a partial pathway to mortality differentials among Veterans diagnosed with TBI^109^ | TBI | 14960 | Health Outcome | Mortality | No | 2
Dobscha, 2009: Associations between race and ethnicity and treatment for chronic pain in the VA110 | Pain (chronic) | 255522 | Utilization | Veterans Rand Health Survey-12, question on receipt of treatment for chronic pain in past year | Mixed/Unclear | 3
Dobscha, 2009: Associations between race and ethnicity and treatment for chronic pain in the VA110 | Pain (chronic) | 255522 | Quality | Veterans Rand Health Survey-12, question on effectiveness of chronic pain care | Yes | 3
Duffy, 2012: Risk of smoking and receipt of cessation services among Veterans with mental disorders^111^ | Smoking cessation | 224193 | Quality | Physician advised quitting, physician recommended medication, physician discussed quitting methods | Yes | 3
Egede, 2010: Longitudinal differences in glycemic control by race/ethnicity among Veterans with type 2 diabetes^112^ | Diabetes | 8813 | Quality | Mean change in hemoglobin A1c, odds of poor control of hemoglobin A1c (<80%) | Yes | 0
Egede, 2011: Longitudinal ethnic differences in multiple cardiovascular risk factor control in a cohort of US adults with diabetes^113^ | Cardiovascular disease, diabetes | 11203 | Quality | Cardiovascular risk factor control (glycemic, blood pressure, LDL-C) | Yes | 1
Egede, 2011: Regional, geographic, and ethnic differences in medication adherence among adults with type 2 diabetes^114^ | Diabetes | 690968 | Quality | Medication adherence | Yes | 3
Egede, 2011: Regional, geographic, and racial/ethnic variation in glycemic control in a national sample of Veterans with diabetes^115^ | Diabetes | 690968 | Quality | Hemoglobin A1c level, poor control of hemoglobin A1c (<80%) | Yes | 3
Egede, 2012: Racial/ethnic disparities in mortality risk among US Veterans with traumatic brain injury^116^ | TBI | 14690 | Health Outcome | Mortality | No | 2
Egede, 2013: Differential impact of longitudinal medication non-adherence on mortality by race/ethnicity among Veterans with diabetes^117^ | Diabetes | 629563 | Health Outcome | Medication nonadherence-associated mortality | No | 3
Ellis, 2009: Racial/ethnic differences in stroke mortality in Veterans^118^ | Cardiovascular (stroke) | 4115 | Health Outcome | All-cause mortality | Yes | 0
Ellis, 2010: Racial/ethnic disparities in poststroke outpatient rehabilitation among Veterans^119^ | Cardiovascular (stroke), rehabilitative care | 4115 | Quality | Receipt of physical therapy, occupational therapy evaluations, visits and procedures | No | 0
Ellis, 2013: Factors associated with delays in seeking treatment for stroke care in Veterans^120^ | Cardiovascular (stroke) | 100 | Utilization | Delay in seeking care for treatment for stroke care | Yes | 0
El-Serag, 2014: Racial differences in the progression to cirrhosis and hepatocellular carcinoma in HCV-infected Veterans^121^ | HCV, cancer (liver) | 149407 | Health Outcome | Risk of cirrhosis or hepatocellular cancer | No | 3
Fischer, 2007: Lack of ethnic differences in end-of-life care in the Veterans Health Administration^122^ | End-of-life (palliative) care | 217 | Quality | Receipt of palliative care measures (advanced directive discussions, treatment of pain if present, symptom-directed plan, do-not-resuscitate orders) | No | 0
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Utilization | Retention in VHA care | Yes | 3
Fischer, 2008: Longitudinal patterns of health system retention among Veterans with schizophrenia or bipolar disorder^123^ | Mental health (serious mental illness) | 164150 | Health Outcome | 5-year survival | No | 3
Fisher, 2006: Barriers to full colon evaluation for a positive fecal occult blood test^124^ | Cancer (colorectal) | 538 | Quality | Full colon evaluation | No | 0
Frei, 2010: Disparities of care for African-Americans and Caucasians with community-acquired pneumonia: a retrospective cohort study^125^ | Pneumonia | 40878 | Utilization | Length of hospital stay | No | 2
Frei, 2010: Disparities of care for African-Americans and Caucasians with community-acquired pneumonia: a retrospective cohort study^125^ | Pneumonia | 40878 | Quality | Antibiotic prescribing, pneumonia processes of care | No | 2
Frei, 2010: Disparities of care for African-Americans and Caucasians with community-acquired pneumonia: a retrospective cohort study^125^ | Pneumonia | 40878 | Health Outcome | 30-day mortality | No | 2
Gaines, 2014: The association between race and prostate cancer risk on initial biopsy in an equal access, multiethnic cohort^126^ | Cancer (prostate) | 887 | Health Outcome | Prostate cancer risk on initial biopsy and prostate cancer grade | Yes | 0
Ganti, 2014: Association between race and survival of patients with non-small-cell lung cancer in the United States Veteran Affairs population^127^ | Cancer | 82414 | Utilization | Received treatment | Yes | 1
Ganti, 2014: Association between race and survival of patients with non-small-cell lung cancer in the United States Veteran Affairs population^127^ | Cancer | 82414 | Quality | Stage-appropriate treatment | Yes | 1
Ganti, 2014: Association between race and survival of patients with non-small-cell lung cancer in the United States Veteran Affairs population^127^ | Cancer | 82414 | Health Outcome | Mortality | No | 1
Garrido, 2014: Benzodiazepine and sedative-hypnotic use among older seriously Ill Veterans: choosing wisely?^128^ | Geriatrics, prescribing | 222 | Quality | Potentially inappropriate use of benzodiazepines or other sedative-hypnotics | No | 0
Gebregziabher, 2011: Using quantile regression to investigate racial disparities in medication non-adherence^129^ | Diabetes | 11272 | Quality | Medication adherence | Yes | 1
Gerber, 2015: Hormone therapy use in women Veterans accessing Veterans Health Administration care: a national cross-sectional study^130^ | Women's health (hormone therapy) | 157195 | Quality | Prescription of hormone therapy | No | 3
Giordano, 2006: Is there a race-based disparity in the survival of Veterans with HIV?^131^ | HIV | 5945 | Health Outcome | Overall survival, hospital mortality (death during hospitalization or within 30 days of discharge), long-term survival (proportion who survived >30 days post-discharge) | No | 1
Goldstein, 2014: Heart matters: Gender and racial differences cardiovascular disease risk factor control among Veterans^132^ | Cardiovascular disease | 24965 | Quality | Measures of blood pressure, LDL-C values, hemoglobin A1c levels | Mixed/Unclear | 2
Gordon, 2006: Racial differences in doctors' information-giving and patients' participation^133^ | Cancer (lung) | 137 | Quality | Provider's information-giving utterances | Mixed/Unclear | 1
Gordon, 2014: Examining patients' trust in physicians and the VA healthcare system in a prospective cohort followed for six-months after an exacerbation of heart failure^134^ | Cardiovascular (heart failure) | 159 | Quality | Trust in physician, trust in VHA | Mixed/Unclear | 2
Graham-Steed, 2013: ‘Race’ and prostate cancer mortality in equal-access healthcare systems^135^ | Cancer (prostate) | 1249 | Health Outcome | Prostate cancer mortality | No | 1
Groeneveld, 2007: Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals^136^ | Cardiovascular (interventions) | 300614 | Utilization | Receipt of care in academic and non-academic hospitals with <30% or ≥30% black inpatients within 90 days | Mixed/Unclear | 3
Grubaugh, 2006: Racial differences in psychiatric symptom patterns and service use in VA primary care clinics^137^ | Mental health | 713 | Utilization | Use of VA services and benefits | Mixed/Unclear | 1
Grubaugh, 2006: Racial differences in psychiatric symptom patterns and service use in VA primary care clinics^137^ | Mental health | 713 | Health Outcome | Rates of trauma, PTSD diagnosis, other psychiatric diagnoses | No | 1
Grubaugh, 2008: Racial disparities in trauma exposure, psychiatric symptoms, and service use among female patients in Veterans Affairs primary care clinics^138^ | Mental health | 183 | Utilization | Service use (inpatient, ED, women's clinic, primary care, mental health) | No | 1
Grubaugh, 2008: Racial disparities in trauma exposure, psychiatric symptoms, and service use among female patients in Veterans Affairs primary care clinics^138^ | Mental health | 183 | Health Outcome | Rates of PTSD, mood disorder, anxiety, substance use, any mental health disorder | No | 1
Grubaugh, 2009: Equity in Veterans Affairs disability claims adjudication in a national sample of Veterans^139^ | Disability | 20048 | Quality | Disability benefits | Mixed/Unclear | 2
Halanych, 2006: Racial/ethnic differences in diabetes care for older Veterans: Accounting for dual health system use changes conclusions^140^ | Diabetes, geriatrics | 5931 | Quality | Hemoglobin A1c, LDL-C screenings, eye exam | Mixed/Unclear | 1
Haskell, 2008: Determinants of hormone therapy discontinuation among female Veterans nationally^141^ | Women's health (hormone therapy) | 36222 | Quality | Hormone therapy discontinuation | No | 2
Haskell, 2009: Pain among Veterans of Operations Enduring Freedom and Iraqi Freedom: Do women and men differ?^142^ | Pain | 153212 | Health Outcome | Pain (reported any pain, reported moderate-severe pain, reported persistent pain) | Yes | 3
Hausmann, 2010: The effect of patient race on total joint replacement recommendations and utilization in the orthopedic setting^143^ | Pain (arthritis and pain management) | 457 | Quality | Receipt of/recommendation for total joint replacement | No | 2
Hausmann, 2011: Orthopedic communication about osteoarthritis treatment: Does patient race matter?^144^ | Pain (osteoarthritis) | 402 | Quality | Communication (Roter Interaction Analysis System, Informed Decision Making Model) | No | 2
Hausmann, 2013: Racial disparities in the monitoring of patients on chronic opioid therapy^145^ | Pain (arthritis and pain management) | 1899 | Quality | Following recommended opioid monitoring and treatment practices | Yes | 0
Hausmann, 2013: Understanding racial and ethnic differences in patient experiences with outpatient health care in Veterans Affairs Medical Centers^146^ | Preventive and ambulatory care | 211459 | Quality | Getting needed care, getting care quickly, how well doctors and nurses communicate, rating of personal doctor, nurse, specialist, overall healthcare rating, use of shared decision-making, pharmacy services | Mixed/Unclear | 3
Hausmann, 2014: Patterns of sex and racial/ethnic differences in patient health care experiences in US Veterans Affairs hospitals^147^ | General health | 50471 | Quality | Patient reports of positive and negative healthcare experiences at VHA facilities | Mixed/Unclear | 2
Heidenreich, 2009: Disparities in VA heart failure care^148^ | Cardiovascular (heart failure) | NR -likely large | Health Outcome | Mortality, rehospitalization | Mixed/Unclear | 2
Higgins, 2014: Persistent pain and comorbidity among Operation Enduring Freedom/Operation Iraqi Freedom/Operation New Dawn Veterans^149^ | Pain (chronic) | 5242 | Health Outcome | Persistent pain (either self-rated scale, pain diagnosis, pain clinic visit, or opioid prescription) | Yes | 1
Hope, 2009: New-onset geriatric epilepsy care: Race, setting of diagnosis, and choice of antiepileptic drug^150^ | Epilepsy | 9682 | Quality | Suboptimal antiepileptic drug prescribing | Yes | 1
Horner, 2007: Factors associated with a provider's recommendation of carotid endarterectomy: implications for understanding disparities in the use of invasive procedures^151^ | Cardiovascular (carotid endarterectomy) | 251 | Quality | Provider recommendation for carotid endarterectomy | No | 2
Hou, 2012: Myelosuppression monitoring after immunomodulator initiation in Veterans with inflammatory bowel disease: a national practice audit^152^ | Gastroenterology (inflammatory bowel disease) | 6045 | Quality | White blood cell monitoring | No | 1
Hou, 2012: Risk of colorectal cancer among Caucasian and African American Veterans with ulcerative colitis^153^ | Cancer (colorectal) | 16490 | Health Outcome | Colorectal cancer | No | 2
Hudson, 2014: Do racial disparities exist in the use of prostate cancer screening and detection tools in Veterans?^154^ | Cancer (prostate, screening) | 275832 | Quality | Prostate-specific antigen screening uptake | Mixed/Unclear | 3
Hunt, 2013: Impact of diabetes control on mortality by race in a national cohort of Veterans^155^ | Diabetes | 892223 | Health Outcome | Mortality | Mixed/Unclear | 4
Ibrahim, 2008: Race, ethnicity and length of hospital stay after knee or hip arthroplasty^156^ | Pain (osteoarthritis) | 18263 | Utilization | Length of hospital stay | No | 2
Ilgen, 2009: Exploratory data mining analysis identifying subgroups of patients with depression who are at high risk for suicide^157^ | Mental health (depression) | 887869 | Health Outcome | Suicide | No | 2
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/rehospitalization | No | 1
Jha, 2010: The concentration of hospital care for black Veterans in Veterans Affairs hospitals: implications for clinical outcomes^159^ | Cardiovascular, hip fracture, stroke, gastrointestinal hemorrhage, and pneumonia | 406537 hospitalizations | Health Outcome | Mortality | Mixed/Unclear | 3
Jia, 2010: Racial and ethnic disparities in post-stroke depression detection^160^ | Cardiovascular (stroke), mental health | 5825 | Health Outcome | Diagnosis of post-stroke depression | No | 1
Jones, 2015: Characteristics and outcomes of patients with advanced chronic systolic heart failure receiving care at the Veterans Affairs versus other hospitals: insights from the Beta-blocker Evaluation of Survival Trial (BEST)^161^ | Cardiovascular (advanced chronic systolic heart failure) | 898 | Health Outcome | Mortality | No | 1
Kales, 2010: Who receives outpatient monitoring during high-risk depression treatment periods?^162^ | Mental health (depression) | 494673 | Utilization | Number of outpatient visits following mental health hospitalization or outpatient initiation of antidepressant medication | No | 3
Kalkonde, 2009: Ethnic disparities in the treatment of dementia in Veterans^163^ | Mental health | 410 | Quality | Neuropsychological testing, depression screening | Mixed/Unclear | 0
Kalkonde, 2009: Ethnic disparities in the treatment of dementia in Veterans^163^ | Mental health | 410 | Health Outcome | Dementia diagnosis | No | 0
Kamalesh, 2007: Stroke mortality and race: does access to care influence outcomes?^164^ | Cardiovascular (stroke) | 55094 | Health Outcome | Mortality | No | 2
Kazerooni, 2014: Predictors of adherence to hormonal contraceptives in a female Veteran population^165^ | Women's health (contraceptive care) | 805 | Health Outcome | Adherence to hormonal contraceptive medication | No | 0
Keyhani, 2014: The underuse of interventions in Veterans with symptomatic carotid stenosis^166^ | Cardiovascular (stroke) | 229 | Quality | Receipt of carotid intervention | Yes | 1
Kilbourne, 2006: Quality of care for substance use disorders in patients with serious mental illness^167^ | Mental health (substance use disorder) | 8083 | Quality | Identification of substance use disorders, initiation of treatment, engagement in treatment | No | 1
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Quality | Receipt of HCV testing, notified ≤60 days | Mixed/Unclear | 2
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Health Outcome | HCV positive | Yes | 2
Kilbourne, 2008: Quality of care for cardiovascular disease-related conditions in patients with and without mental disorders^169^ | Cardiovascular (hypertension) | 24016 | Quality | Poor hypertension control (blood pressure ≥160/100) and good hypertension control (blood pressure ≤140/90). | Mixed/Unclear | 2
Kimerling, 2011: Military sexual trauma and patient perceptions of Veteran Health Administration health care quality^170^ | Mental health (military sexual trauma) | 164632 | Quality | Patient satisfaction with VHA outpatient care | Yes | 3
Kokkinos, 2009: Exercise Capacity and All-Cause Mortality in African American and Caucasian Men with Type 2 Diabetes^171^ | Diabetes | 3148 | Health Outcome | All-cause mortality | Yes | 1
Koo, 2015: Race-ethnicity and gender differences in VA health care service utilization among US Veterans of recent conflicts^172^ | Preventive and ambulatory care | 309050 | Utilization | Healthcare utilization | Mixed/Unclear | 3
Koscuiszka, 2012: Impact of race on survival in patients with clinically nonmetastatic prostate cancer who deferred primary treatment^173^ | Cancer (prostate) | 518 | Health Outcome | Mortality | Mixed/Unclear | 0
Koshiol, 2011: Racial differences in chronic immune stimulatory conditions and risk of non-Hodgkin's lymphoma in Veterans from the United States^174^ | Cancer (non-Hodgkin lymphoma) | 9496 | Health Outcome | Risk of non-Hodgkin lymphoma diagnosis by associated condition (infections, allergies, autoimmune conditions) | Mixed/Unclear | 1
Kovesdy, 2013: Survival advantage in black versus white men with CKD: effect of estimated GFR and case mix^175^ | Renal (chronic kidney disease) | 570808 | Health Outcome | 5-year mortality | Mixed/Unclear | 3
Kovesdy, 2015: Association of race with mortality and cardiovascular events in a large cohort of US Veterans^176^ | Cardiovascular disease | 3072966 | Health Outcome | Mortality | Mixed/Unclear | 3
Kressin, 2007: Functional status outcomes among white and African-American cardiac patients in an equal access system^177^ | Cardiovascular | 1022 | Quality | Receipt of percutaneous transluminal coronary angioplasty, cardiac catheterization, coronary artery bypass grafting | Mixed/Unclear | 2
Kressin, 2007: Functional status outcomes among white and African-American cardiac patients in an equal access system^177^ | Cardiovascular | 1022 | Health Outcome | Functional status | No | 2
Kressin, 2007: Hypertensive patients' race, health beliefs, process of care, and medication adherence^178^ | Cardiovascular disease | 793 | Quality | Antihypertensive medication adherence | No | 1
Landrum, 2012: Race and income association with health service utilization for Veterans with heart failure^179^ | Cardiovascular (heart failure) | 149 | Utilization | Heart failure-related outcomes (30-day, 90-day, 1-year and total readmissions, ED visits and total bed days of care) | No | 0
Landrum, 2012: Reasons for underuse of recommended therapies for colorectal and lung cancer in the Veterans Health Administration^180^ | Cancer | 584 | Quality | Access, recommendation and receipt of recommended cancer therapy | Mixed/Unclear | 1
Liang, 2013: Outcomes and predictors of incisional surgical site infection in stoma reversal^181^ | Surgery, surgical site infection | 128 | Health Outcome | Surgical site infections | No | 0
Luca, 2015: Mental health care utilization: how race, ethnicity and veteran status are associated with seeking help^182^ | Mental health | 1124 | Utilization | Receipt of mental health treatment | No | 1
Luncheon, 2012: Health-related quality of life among US Veterans and civilians by race and ethnicity^183^ | Quality of life, health-related | 110000 | Health Outcome | Physically unhealthy days, mentally unhealthy days, recent activity limitation days | No | 3
Lynch, 2010: Racial disparities in all-cause mortality among Veterans with type 2 diabetes^184^ | Diabetes | 8812 | Health Outcome | Time to death | No | 0
Lynch, 2015: Geographic and racial/ethnic variations in patterns of multimorbidity burden in patients with type 2 diabetes^185^ | Diabetes | 892223 | Health Outcome | Multimorbidity | Yes | 3
Mackenzie, 2010: Impact of rural residence on survival of male Veterans affairs patients after age 65^186^ | Mortality in older adults | 372463 | Health Outcome | Mortality | No | 3
Mattocks, 2015: Infertility care among OEF/OIF/OND women Veterans in the Department of Veterans Affairs^187^ | Women's health (reproductive health) | 1323 | Quality | Received an infertility assessment | Mixed/Unclear | 0
May, 2014: Low uptake of colorectal cancer screening among African Americans in an integrated Veterans Affairs health care network^188^ | Cancer (colorectal) | 357 | Quality | Screening uptake, time to screening | Yes | 1
Maynard, 2006: The use of percutaneous coronary intervention in black and white Veterans with acute myocardial infarction^189^ | Cardiovascular (acute coronary syndrome) | 4209 | Quality | Use of percutaneous coronary intervention, 30-day rates of cardiac catheterization, and coronary artery bypass surgery | No | 1
Mehta, 2010: Racial disparities in prescriptions for cardioprotective drugs and cardiac outcomes in Veterans Affairs Hospitals^190^ | Cardiovascular disease | 474565 | Quality | Prescriptions for cardioprotective drugs (aspirin, beta-blocker, statin, angiotensin-converting enzyme inhibitor) | Mixed/Unclear | 3
Mehta, 2010: Racial disparities in prescriptions for cardioprotective drugs and cardiac outcomes in Veterans Affairs Hospitals^190^ | Cardiovascular disease | 474565 | Health Outcome | Angina, acute myocardial infarction | Yes | 3
Merkow, 2013: Efficiency of colorectal cancer care among veterans: analysis of treatment wait times at Veterans Affairs Medical Centers^191^ | Cancer (colon, rectal) | 17487 | Quality | Wait time from diagnosis to first-course therapy for colon and rectal cancers | Mixed/Unclear | 2
Merriman, 2006: Racial difference in mortality among U.S. Veterans with HCV/HIV coinfection^192^ | HCV, HIV | 743 | Health Outcome | 3-year all-cause mortality | No | 0
Meyers, 2008: Racial differences in mortality among men hospitalized in military hospitals^193^ | Cardiovascular, gastrointestinal hemorrhage, stroke, diabetes | 14122 | Health Outcome | Hospital mortality | No | 2
Moore, 2015: Racial, income, and marital status disparities in hospital readmissions within a Veterans-integrated health care network^194^ | Inpatient/acute care | 8718 | Utilization | Number of hospital readmissions | No | 1
Morasco, 2010: Clinical characteristics of Veterans prescribed high doses of opioid medications for chronic non-cancer pain^195^ | Pain (arthritis and pain management) | 1478 | Health Outcome | High-dose opioid use | No | 0
Morikawa, 2008: Counting alleles in single lesions of prostate tumors from ethnically diverse patients^196^ | Cancer (prostate) | 153 | Quality | 8p allelic status | No | 1
Myaskovsky, 2012: Perceived discrimination predicts longer time to be accepted for kidney transplant^197^ | Renal (end-stage renal disease) | 127 | Quality | Time to be accepted for kidney transplant | No | 1
Nguyen, 2014: Risk factors for Barrett's esophagus compared between African Americans and non-Hispanic Whites^198^ | Cancer (esophageal adenocarcinoma) | 1952 | Health Outcome | Diagnosis of Barrett's esophagus | No | 0
Peiris, 2011: Race and vitamin D status and monitoring in male Veterans^199^ | Preventive and ambulatory care | 14148 | Quality | Follow-up testing for vitamin D | Yes | 2
Phillips, 2015: Racial/ethnic disparities in monitoring metabolic parameters for patients with schizophrenia receiving antipsychotic medications^200^ | Mental health (schizophrenia) | 30258 | Quality | Monitoring of metabolic dysregulation | Yes | 1
Polsky, 2007: Is lower 30-day mortality posthospital admission among blacks unique to the Veterans Affairs health care system?^201^ | Pneumonia, congestive heart failure, gastrointestinal bleeding, hip fracture, stroke, or acute myocardial infarction | 369155 | Health Outcome | 30-day mortality | No | 3
Polsky, 2008: Short- and long-term mortality after an acute illness for elderly whites and blacks^202^ | Pneumonia, congestive heart failure, gastrointestinal bleeding, hip fracture, stroke, or acute myocardial infarction | 155529 | Health Outcome | 30-day to 2-year mortality | Mixed/Unclear | 3
Poon, 2010: Racial/ethnic differences in blood pressure control and medication utilization in a cohort of older Veterans with dementia^203^ | Cardiovascular (hypertension), Dementia | 304 | Quality | Use of hypertensive medications, blood pressure control, use of dementia medications, MMSE score | Mixed/Unclear | -1
Poon, 2009: Racial/ethnic disparities in medication use among Veterans with hypertension and dementia: a national cohort study^204^ | Preventive and ambulatory care | 56561 | Quality | Prevalence of each medication class and medication adherence | Yes | 2
Pugh, 2006: Assessing potentially inappropriate prescribing in the elderly Veterans Affairs population using the HEDIS 2006 quality measure^205^ | Geriatrics, prescribing | 1096361 | Quality | Potentially inappropriate prescribing based on HEDIS criteria | No | 3
Pugh, 2008: Potentially inappropriate prescribing for the elderly: effects of geriatric care at the patient and health care system level^206^ | Geriatrics, prescribing | 714130 | Quality | Potentially inappropriate prescribing in the elderly | No | 3
Pugh, 2011: Trends in use of high-risk medications for older Veterans: 2004 to 2006^207^ | Geriatrics, prescribing | 1567467 | Quality | Use of high-risk medications for the elderly | Mixed/Unclear | 3
Quinones, 2014: Racial and ethnic differences in receipt of antidepressants and psychotherapy by Veterans with chronic depression^208^ | Mental health (depression) | 62095 | Quality | Adequate depression care | Mixed/Unclear | 2
Rawaf, 2007: Exploring racial and sociodemographic trends in physician behavior, physician trust and their association with blood pressure control^209^ | Cardiovascular disease | 793 | Quality | Blood pressure control | No | 1
Richardson, 2008: Effect of race/ethnicity and persistent recognition of depression on mortality in elderly men with type 2 diabetes and depression^210^ | Diabetes | 14500 | Health Outcome | Mortality | No | 1
Robinson, 2010: Ethnic disparities are reduced in VA colon cancer patients^211^ | Cancer (colorectal) | 214 | Quality | Stage of disease at presentation, mean times from diagnosis to surgical resection, time from surgical consultation to surgery, mean time to adjuvant therapy with among stage III patients | No | 0
Robinson, 2010: Ethnic disparities are reduced in VA colon cancer patients^211^ | Cancer (colorectal) | 214 | Health Outcome | Survival time | No | 0
Rogers, 2014: Healthcare utilization following mild traumatic brain injury in female Veterans^212^ | Preventive and ambulatory care | 12144 | Utilization | Healthcare utilization, outpatient | Mixed/Unclear | 2
Rose, 2013: Racial/ethnic differences in cardiovascular risk factors among women Veterans^213^ | Cardiovascular disease risk factors | 3611 | Quality | Cardiovascular disease risk factors | Yes | 1
Rose, 2013: Racial/ethnic differences in cardiovascular risk factors among women Veterans^213^ | Cardiovascular disease risk factors | 3611 | Health Outcome | Diabetes diagnosis | Yes | 1
Rosen, 2013: Racial differences in Veterans' satisfaction with examination of disability from posttraumatic stress disorder^214^ | Mental health (PTSD) | 384 | Quality | Patient evaluation of interview quality | Yes | 2
Roumie, 2011: Prevalence of inadequate blood pressure control among veterans after acute ischemic stroke hospitalization: a retrospective cohort^215^ | Cardiovascular (stroke, hypertension) | 3640 | Quality | BP control at the time of discharge and 6-month follow-up in patients hospitalized for stroke | Mixed/Unclear | 1
Sabounchi, 2012: Impact of race on colorectal cancer^216^ | Cancer (colorectal) | 300 | Quality | Access to care | Mixed/Unclear | -1
Sabounchi, 2012: Impact of race on colorectal cancer^216^ | Cancer (colorectal) | 300 | Health Outcome | Mortality | No | -1
Sajatovic, 2007: Treatment adherence with lithium and anticonvulsant medications among patients with bipolar disorder^217^ | Mental health (bipolar) | 44637 | Quality | Medication adherence | Yes | 1
Sambamoorthi, 2010: Depression treatment patterns among women Veterans with cardiovascular conditions or diabetes^218^ | Women's health (cardiovascular health or diabetes) | 7354 | Utilization | Depression services (antidepressants, psychotherapy) | Mixed/Unclear | 0
Sambamoorthi, 2012: Decomposing gender differences in low-density lipoprotein cholesterol among Veterans with or at risk for cardiovascular illness^219^ | Cardiovascular (lipid management) | 527568 | Quality | LDL-C greater than or equal to 130 | Mixed/Unclear | 3
Samuel, 2014: Racial disparities in cancer care in the Veterans Affairs health care system and the role of site of care^220^ | Cancer | 76707 | Quality | Early-stage diagnosis, receipt of surgery | Yes | 2
Samuel, 2014: Racial disparities in cancer care in the Veterans Affairs health care system and the role of site of care^220^ | Cancer | 76707 | Health Outcome | Survival | Mixed/Unclear | 2
Sandulache, 2013: Impact of race/ethnicity on laryngeal cancer in patients treated at a Veterans Affairs Medical Center^221^ | Cancer (laryngeal) | 205 | Quality | Patient and tumor characteristics, compliance with National Comprehensive Cancer Network guidelines | No | 0
Sandulache, 2013: Impact of race/ethnicity on laryngeal cancer in patients treated at a Veterans Affairs Medical Center^221^ | Cancer (laryngeal) | 205 | Health Outcome | Survival outcomes | No | 0
Sarrazin, 2009: Racial differences in mortality among Veterans hospitalized for exacerbation of chronic obstructive pulmonary disease^222^ | Chronic obstructive pulmonary disease | 50979 | Health Outcome | Mortality | No | 2
Schreiber, 2014: Impact of race in a predominantly African-American population of patients with low/intermediate risk prostate cancer undergoing radical prostatectomy within an equal access care institution^223^ | Cancer (prostate) | 222 | Quality | Biochemical failure (prostate-specific antigen >0.2 ng/mL followed by repeat measure higher than 0.2 ng/mL or initiation of salvage treatment), distant control | Mixed/Unclear | 0
| Cancer (prostate) | 222 | Health Outcome | Survival | No | 0
Schwartz, 2016: Racial disparity in adherence to positive airway pressure among US Veterans^224^ | Obstructive sleep apnea | 2172 | Quality | Continuous positive airway pressure compliance | Yes | 0
Seal, 2007: Bringing the war back home: Mental health disorders among 103 788 US Veterans returning from Iraq and Afghanistan seen at Department of Veterans Affairs Facilities^225^ | Mental health | 103788 | Health Outcome | PTSD or other mental health diagnoses | No | 3
Seal, 2011: Substance use disorders in Iraq and Afghanistan Veterans in VA healthcare, 2001-2010: Implications for screening, diagnosis and treatment^226^ | Mental health (substance use disorder) | 456502 | Health Outcome | Presence or absence of substance use disorders (alcohol or drug use disorder) | Mixed/Unclear | 3
Shaw, 2014: Posttraumatic stress disorder and risk of spontaneous preterm birth^227^ | Women's health (preterm birth), mental health (PTSD) | 16334 | Health Outcome | Spontaneous preterm birth | Yes | 2
Shimada, 2008: Advances in patient safety: racial disparities in Patient Safety Indicator (PSI) rates in the Veterans Health Administration^228^ | Inpatient care | 1032103 | Quality | Patient safety indicators | Mixed/Unclear | 2
Shimada, 2008: Racial disparities in patient safety indicator (PSI) rates in the Veterans Health Administration^229^ | Surgery (postoperative and surgical complications) | 1032103 | Health Outcome | Death in low mortality Diagnosis-Related Groups | Mixed/Unclear | 3
Spoont, 2009: Race and ethnicity as factors in mental health service use among Veterans with PTSD^230^ | Mental health (PTSD) | 20284 | Utilization | Mental health care receipt (medication prescription, counseling) | No | 2
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | Mixed/Unclear | 2
Taber, 2016: Overall graft loss versus death-censored graft loss: unmasking the magnitude of racial disparities in outcomes among US kidney transplant recipients^232^ | Renal | 4918 | Health Outcome | Overall graft loss, death and death-censored graft loss | Mixed/Unclear | 1
Tiwari, 2008: Guideline-consistent antidepressant treatment patterns among Veterans with diabetes and major depressive disorder^233^ | Mental health (depression), diabetes | 3953 | Quality | Proportion who have guideline-consistent antidepressant treatment | Yes | 1
Trivedi, 2011: Despite improved quality of care in the Veterans Affairs health system, racial disparity persists for important clinical outcomes^234^ | Preventive and ambulatory care | 1126254 | Quality | Quality of care measures: diabetes (control of hemoglobin A1c, control of LDL-C), cardiovascular disease (control of LDL-C), hypertension control | Mixed/Unclear | 3
Tsai, 2014: The effects of race and other socioeconomic factors on health service use among American military Veterans^235^ | Preventive and ambulatory care | 19270 | Utilization | Health service use | Mixed/Unclear | 2
Tseng, 2006: Diabetes care among Veteran women with disability^236^ | Diabetes | 2344 | Quality | Hemoglobin A1c and LDL-C screening and control | Mixed/Unclear | 1
Tseng, 2007: The association between mental health functioning and nontraumatic lower extremity amputations in Veterans with diabetes^237^ | Diabetes | 114890 | Health Outcome | Major and minor non-traumatic lower extremity amputations | Mixed/Unclear | 3
Tseng, 2011: Trends in initial lower extremity amputation rates among Veterans Health Administration Health Care System users from 2000 to 2004^238^ | Diabetes | 405580 to 739377 | Health Outcome | Lower extremity amputation | No | 3
Twombly, 2010: Diabetes care in black and white Veterans in the southeastern U.S.^239^ | Diabetes | 4080 | Utilization | Number of outpatient visits | No | 1
Twombly, 2010: Diabetes care in black and white Veterans in the southeastern U.S.^239^ | Diabetes | 4080 | Quality | Hemoglobin A1c level, number of random plasma glucose measurements, and number of hemoglobin A1c measurements | Mixed/Unclear | 1
Vimalananda, 2013: Cardiovascular disease risk factors among women Veterans at VA medical facilities^240^ | Cardiovascular disease | 2515015 | Quality | Hypertension, hyperlipidemia, obesity | Mixed/Unclear | 2
Vimalananda, 2013: Cardiovascular disease risk factors among women Veterans at VA medical facilities^240^ | Cardiovascular disease | 2515015 | Health Outcome | Diabetes prevalence | Yes | 2
Volpp, 2007: Is thirty-day hospital mortality really lower for black Veterans compared with white Veterans?^241^ | Pneumonia, congestive heart failure, gastrointestinal bleeding, hip fracture, stroke, or acute myocardial infarction | 406550 | Health Outcome | 30-day mortality after hospitalization | Mixed/Unclear | 3
Washington, 2009: Women Veterans ambulatory care use project, phase II^242^ | Women's health | 2174 | Utilization | Utilization of VHA mental health care | Yes | 0
Washington, 2011: VA facility determinants of racial-ethnic variations in quality of care^243^ | Preventive and ambulatory care | NR -likely large | Quality | Control of blood pressure, LDL-cholesterol, and diabetes, colorectal cancer screening, receipt of immunizations | Yes | 2
Wendel, 2006: Racial and ethnic disparities in the control of cardiovascular disease risk factors in Southwest American Veterans with type 2 diabetes: the Diabetes Outcomes in Veterans Study^244^ | Diabetes, cardiovascular disease risk | 338 | Quality | Glycemic control, insulin treatment intensity, lipid levels, and blood pressure control | Mixed/Unclear | 1
Whittle, 2006: Racial differences in prevalence of coronary obstructions among men with positive nuclear imaging studies^245^ | Cardiovascular disease | 1025 | Health Outcome | Significant coronary obstruction | No | 2
Whittle, 2011: Better hypertension and lipid care in racially diverse, Veterans at risk^246^ | Cardiovascular (acute coronary syndrome) | 36000 | Health Outcome | Mortality | Yes | 2
Williams, 2013: Influence of comorbidity on racial differences in receipt of surgery among US Veterans with early-stage non-small-cell lung cancer^247^ | Cancer (lung) | 1314 | Quality | Access to care (non-small-cell lung cancer surgery) | Yes | 1
Yang, 2006: Long-term morbidity and mortality among a sample of cocaine-dependent black and white Veterans^248^ | Mental health (substance use disorder, cocaine dependence) | 294 | Health Outcome | Mortality, utilization of medical, mental health, drug, and alcohol services | No | 1
Zeber, 2007: Self-reported access to general medical and psychiatric care among Veterans with bipolar disorder^249^ | Mental health (bipolar) | 435 | Utilization | Patient perception of access to health and mental health | No | 0
Zeber, 2009: Perceived access to general medical and psychiatric care among Veterans with bipolar disorder^250^ | Preventive and ambulatory care | 435 | Utilization | Obtaining necessary care | Mixed/Unclear | 0
Zeber, 2011: Medication adherence, ethnicity, and the influence of multiple psychosocial and financial barriers^251^ | Mental health | 435 | Quality | Medication adherence | Mixed/Unclear | 0
Zevallos, 2016: Impact of race on oropharyngeal squamous cell carcinoma presentation and outcomes among Veterans^252^ | Cancer (oropharyngeal squamous cell carcinoma) | 158 | Health Outcome | Survival | No | 0
Zickmund, 2015: Racial and ethnic disparities in satisfaction with VA care^253^ | Utilization (satisfaction) | 1219 | Quality | Patient satisfaction (access) | No | 1
Zivin, 2007: Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: Associations with patient and treatment setting characteristics^254^ | Mental health (depression) | 807694 | Health Outcome | Suicide mortality | No | 3
Zullig, 2013: An examination of racial differences in process and outcome of colorectal cancer care quality among users of the Veterans Affairs Health Care System^255^ | Cancer (colorectal) | 2022 | Quality | Time from surgery to initiation of adjuvant chemotherapy, surgery to surveillance colonoscopy, and surgery to death | Mixed/Unclear | 1
Zullig, 2013: An examination of racial differences in process and outcome of colorectal cancer care quality among users of the Veterans Affairs Health Care System^255^ | Cancer (colorectal) | 2022 | Health Outcome | Time from surgery to death | No | 1
Zullig, 2013: Examining potential colorectal cancer care disparities in the Veterans Affairs health care system^256^ | Cancer (colorectal) | 2022 | Quality | Guideline-concordant care | No | 1
Zullig, 2013: The association of race with timeliness of care and survival among Veterans Affairs health care system patients with late-stage non-small cell lung cancer^257^ | Cancer (non-small cell lung carcinoma) | 2200 | Quality | Time to receiving recommended care (treatment initiation and palliative care) | No | 1
Zullig, 2013: The association of race with timeliness of care and survival among Veterans Affairs health care system patients with late-stage non-small cell lung cancer^257^ | Cancer (non-small cell lung carcinoma) | 2200 | Health Outcome | Survival | No | 1