# APPENDIX D KEY QUESTION 1 STUDY DISTRIBUTION BY CLINICAL AREA AND CATEGORY

Mental health represented the most widely studied clinical area, followed by cardiovascular disease, cancer, and diabetes. Most of the studies in cardiovascular disease (69.2%), cancer (76.3%), and diabetes (63.3%) reported quality of care outcomes. The table below shows the distribution of studies by clinical area and outcome category.

Table Distribution of Studies by Clinical Area and Outcome Category

Clinical area | Total studies^a^ N (%)^b^ | Utilization N (%)^c^ | Quality N (%)^c^ | Health Outcome N (%)^c^
Mental health | 100 (27.6) | 35 (35.0) | 36 (36.0) | 48 (48.0)
Cardiovascular | 52 (14.4) | 4 (7.7) | 36 (69.2) | 21 (40.4)
Cancer | 38 (10.5) | 2 (5.3) | 29 (76.3) | 18 (47.4)
Diabetes | 30 (8.3) | 2 (6.7) | 19 (63.3) | 12 (40.0)
Pain | 19 (5.2) | 5 (26.3) | 10 (52.6) | 7 (36.8)
Utilization | 14 (3.9) | 12 (85.7) | 2 (14.3) | 2 (14.3)
Women's health | 14 (3.9) | 5 (35.7) | 6 (42.9) | 4 (28.6)
Preventive and ambulatory care | 12 (3.3) | 4 (33.3) | 8 (66.7)
General health | 10 (2.8) | 3 (30.0) | 7 (70.0) | 4 (40.0)
Hepatitis C | 8 (2.2) | 1 (12.5) | 6 (75.0) | 4 (50.0)
HIV | 7 (1.9) | 2 (28.6) | 2 (28.6) | 4 (57.1)
Geriatrics, Prescribing | 6 (1.7) | | 6 (100.0)
Renal | 6 (1.7) | | 1 (16.7) | 5 (83.3)
Surgery | 6 (1.7) | 2 (33.3) | 1 (16.7) | 4 (66.7)
Dementia | 5 (1.4) | 1 (20.0) | 3 (60.0) | 2 (40.0)
Inpatient care | 4 (1.1) | 1 (25.0) | 3 (75.0)
Physical & mental health status | 4 (1.1) | | | 4 (100.0)
Pneumonia | 4 (1.1) | 1 (25.0) | 1 (25.0) | 4 (100.0)
End-of-life care | 3 (0.8) | | 3 (100.0)
Quality of life, health-related | 3 (0.8) | | | 3 (100.0)
Traumatic brain injury | 3 (0.8) | 2 (66.7) | 2 | (66.7)
Access | 2 (0.6) | 2 (100.0)
Chronic disease | 2 (0.6) | | | 1 (100.0)
Chronic obstructive pulmonary disease | 2 (0.6) | | 1 (50.0) | 1 (50.0)
Disability | 2 (0.6) | | 2 (100.0)
Mortality | 2 (0.6) | | | 2 (100.0)
Smoking cessation | 2 (0.6) | | 2 (100.0)
Clinical pharmacy services | 1 (0.3) | 1 (100.0)
Dental | 1 (0.3) | | 1 (100.0)
Epilepsy | 1 (0.3) | | 1 (100.0)
Gastroenterology | 1 (0.3) | | 1 (100.0)
Obstructive sleep apnea | 1 (0.3) | | 1 (100.0)
Prosthetic care | 1 (0.3) | | 1 (100.0)
Sleep | 1 (0.3) | | 1 (100.0)
Transplantation | 1 (0.3) | | 1 (100.0) | 1 (100.0)
Varices care | 1 (0.3) | | 1 (100.0)
Venous thromboembolism | 1 (0.3) | | 1 (100.0) | 1 (100.0)
Vitamin D levels | 1 (0.3) | 1 (100.0) | 1 (100.0)
Wound care | 1 (0.3) | 1 (100.0) | | 1 (100.0)

a Ten studies were represented in more than one clinical area.

b Percent of total included studies (N=362).

c Percent of total studies in clinical area. Some studies reported outcomes in multiple categories.