# APPENDIX C STUDY SELECTION

[underlined: Inclusion Criteria]
1. Language: Is the full text of the article in English?; Yes.................................................................................Proceed to #2; No...............................................................................Code X1. STOP; 2. Population: Are the participants exclusively Veterans/at a VA Medical Center?; Yes.................................................................................Proceed to #3; No.............................Code X2. Add code B if retaining for background/discussion. STOP; 3. Study Design: Is the study original research, a systematic review or meta-analysis?; Yes.................................................................................Proceed to #4; No.............................Code X3. Add code B if retaining for background/discussion. STOP; 4. Comparator: The study's primary comparison is populations/groups for whom a disparity may; exist (eg, race/ethnicity, gender, LGBT, age, mental illness, physical or cognitive disability,; geographic location, era of military service, etc.)?; Yes.................................................................................Proceed to #5; No.............................Code X4. Add code B if retaining for background/discussion. STOP; 5. Outcomes: Does the study report one or more of the following outcomes: utilization, quality (ie,; patient outcomes [eg, mortality, morbidity], intermediate/process of care measures, patient; evaluations of care, direct observation [eg, communication patterns], other [eg, medication; adherence, health education, etc.? Mediators (ie, system level [eg, distribution of services],; provider level [eg, racial bias], patient level [eg, trust], provider-patient level [eg,; communication]) without an accompanying utilization, quality, intermediate/process of care,; patient evaluations of care, direct observation, other outcome of interest are excluded.; Yes.................................................................................Proceed to #6; No.............................Code X5. Add code B if retaining for background/discussion. STOP; 6. Intervention: Does the study include interventions that were designed specifically for, or are; being specifically used to reduce disparities, or examine mediators associated with health; disparities for Veterans?; Yes.......................................................................Code I for KQ2. STOP; No.........................................................................Code I for KQ1. STOP
[underlined: Key Questions]
KQ1. For what groups/populations, and in which clinical areas are health and healthcare disparities prevalent within the VHA? KQ2. What are the effects of interventions implemented within the VHA to reduce health disparities? KQ3. What research projects have been funded by the VA Office of Research and Development (ORD) to address any of the components in the other key questions from 2010 to present?