# APPENDIX A SEARCH STRATEGIES

## LIST OF VA CENTERS CONTACTED FOR STUDIES

Mental Illness Research, Education and Clinical Centers (MIRECCs)
New England MIRECC - VISN 1 (http://www.mirecc.va.gov/visn1/)
Center for Integrated Healthcare - VISN 2 (CIH) (http://www.mirecc.va.gov/cih-visn2/)
Center of Excellence for Suicide Prevention - VISN 2 (http://www.mirecc.va.gov/suicideprevention/)
VISN 3 MIRECC (http://www.mirecc.va.gov/visn3/)
VISN 4 MIRECC (http://www.mirecc.va.gov/visn4/)
VA Capitol Health Care Network MIRECC - VISN 5 (http://www.mirecc.va.gov/visn5/)
Mid-Atlantic MIRECC - VISN 6 (http://www.mirecc.va.gov/visn6/)
South Central MIRECC - VISN 16 (http://www.mirecc.va.gov/visn16/)
VISN 17 Center of Excellence (COE) for Research on Returning War Veterans (http://www.mirecc.va.gov/visn17/)
Rocky Mountain Network MIRECC - VISN 19 (http://www.mirecc.va.gov/visn19/)
Northwest MIRECC - VISN 20 (http://www.mirecc.va.gov/visn20/)
Sierra Pacific MIRECC - VISN 21 (http://www.mirecc.va.gov/visn21/)
Desert Pacific MIRECC - VISN 22 (http://www.mirecc.va.gov/visn22/)
The National Center for PTSD (http://www.ptsd.va.gov/)
Geriatric Research Education and Clinical Centers (GRECCs)
Ann Arbor (http://www.va.gov/GRECC/Ann_Arbor_GRECC.asp)
Baltimore (http://www.va.gov/GRECC/Baltimore_MD_GRECC.asp)
Birmingham/Atlanta (http://www.va.gov/GRECC/Birmingham_Atlanta_GRECC.asp)
Bronx/New York Harbor (http://www.va.gov/GRECC/Bronx_New_York_Harbor_GRECC.asp)
Cleveland (http://www.va.gov/GRECC/Cleveland_GRECC.asp)
Durham (http://www.va.gov/GRECC/Durham_GRECC.asp)
Gainesville (http://www.va.gov/GRECC/Gainesville_GRECC.asp)
Greater Los Angeles (http://www.va.gov/GRECC/Greater_Los_Angeles_GRECC.asp)
Little Rock (http://www.va.gov/GRECC/Little_Rock_GRECC.asp)
Madison (http://www.va.gov/GRECC/Madison_GRECC.asp)
Miami (http://www.va.gov/GRECC/Miami_GRECC.asp)
Minneapolis (http://www.va.gov/GRECC/Minneapolis_GRECC.asp)
New England (Bedford Division) (http://www.va.gov/GRECC/New_England_GRECC_Bedford_Division.asp)
New England (Boston Division) (http://www.va.gov/GRECC/New_England_GRECC_Boston_Division.asp)
Palo Alto (http://www.va.gov/GRECC/Palo_Alto_GRECC.asp)
Pittsburgh (http://www.va.gov/GRECC/Pittsburgh_GRECC.asp)
Puget Sound (Seattle & American Lake Divisions) (http://www.va.gov/GRECC/Puget_Sound_GRECC_Seattle_and_American_Lake_Divisions.asp)
Salt Lake City (http://www.va.gov/GRECC/Salt_Lake_City_GRECC.asp)
San Antonio (http://www.va.gov/GRECC/San_Antonio_GRECC.asp)
Tennessee Valley (http://www.va.gov/GRECC/Tennessee_Valley_GRECC.asp)
Other Centers
Ann Arbor, MI: Center for Clinical Management Research (CCMR) (http://www.hsrd.research.va.gov/centers/ccmr.cfm)
Bedford, MA and Boston, MA: Center for Healthcare Organization and Implementation Research (CHOIR) (http://www.hsrd.research.va.gov/centers/choir.cfm)
Charleston, SC: Charleston Health Equity and Rural Outreach Innovation Center (HEROIC) (http://www.hsrd.research.va.gov/centers/heroic.cfm)
Durham, NC: [underlined: Center for Health Services Research in Primary Care]
Hines, IL: [underlined: Center of Innovation for Complex Chronic Healthcare (CINCCH)]
Houston, TX: [underlined: Center for Innovations in Quality, Effectiveness and Safety (IQuESt)]
Indianapolis, IN: [underlined: Center for Health Information and Communication (CHIC)]
Iowa City, IA: [underlined: Center for Comprehensive Access & Delivery Research and Evaluation (CADRE)]
Los Angeles, CA: Center for the Study of Healthcare Innovation, Implementation and Policy (CSHIIP) (http://www.hsrd.research.va.gov/centers/cshiip.cfm)
Minneapolis, MN: [underlined: Center for Chronic Disease Outcomes Research (CCDOR)]
North Florida/South Georgia and Tampa: Center of Innovation on Disability and Rehabilitation Research (CINDRR) (http://www.hsrd.research.va.gov/centers/cidrr8.cfm)
North Little Rock, AR: Center for Mental Healthcare and Outcomes Research (CeMHOR) (http://www.hsrd.research.va.gov/centers/cemhor.cfm)
Palo Alto, CA: Center for Innovation to Implementation (Ci2i): Fostering High Value Care (http://www.hsrd.research.va.gov/centers/ci2i.cfm)
Pittsburgh and Philadelphia, PA: Center for Health Equity Research & Promotion (CHERP) (http://www.hsrd.research.va.gov/centers/cherp.cfm)
Portland, OR: Center to Improve Veteran Involvement in Care (CIVIC) (http://www.hsrd.research.va.gov/centers/civic.cfm)
Providence, RI: Center of Innovation in Long-Term Services and Supports for Vulnerable Veterans (http://www.hsrd.research.va.gov/centers/providence.cfm)
Salt Lake City, UT: Informatics, Decision-Enhancement and Analytic Sciences Center (IDEAS 2.0) (http://www.hsrd.research.va.gov/centers/ideas2.cfm)
Seattle, WA and Denver, CO: Center of Innovation for Veteran-Centered and Value-Driven Care (http://www.hsrd.research.va.gov/centers/seattle-denver.cfm)
West Haven, CT: Pain Research, Informatics, Multi-morbidities, and Education (PRIME) Center (http://www.hsrd.research.va.gov/centers/prime.cfm)

## SEARCH STRATEGY

### DATABASES/WEBSITES

- Medline
- PubMed (non-Medline materials)
- CINAHL
- PsycINFO
- EBM Reviews (CDSR, DARE, HTA, Cochrane CENTRAL)
- Social Services Abstracts
- Sociological Abstracts
- HSR&D
- ESP
- Clinicaltrials.gov

### SEARCH STRATEGIES

#### Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to November Week 3 2015, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 07, 2016

Date Searched: January 8, 2016

1 | Healthcare disparities/ | 9988
2 | Health equity/ | 18
3 | Health status disparities/ | 9840
4 | Health services accessibility/ | 57487
5 | “Health Services Needs and Demand”/ | 45916
6 | Delivery of health care/ | 72039
7 | Quality of health care/ | 62070
8 | Attitude of health personnel/ | 99786
9 | Professional-patient relations/ | 23109
10 | Physician-patient relations/ | 64369
11 | Nurse-patient relations/ | 32266
12 | Dentist-patient relations/ | 7810
13 | Patient satisfaction/ | 65439
14 | (Discriminat* or Disparit* or parity or Inequal* or Unequal or equal or Inequit* or Equity or equitable or undertreat* or under-treat* or overtreat* or over-treat* or access or accessible or accessibility).tw. | 733163
15 | or/1-14 | 1147372
16 | Transgendered persons/ or health services for transgendered persons/ | 673
17 | Homosexuality/ | 12115
18 | Homosexuality, male/ | 11279
19 | Homosexuality, female/ | 2942
20 | Bisexuality/ | 3134
21 | Transsexualism/ | 3152
22 | (LGBT* or lesbian* or homosexual* or gay or gays or bisexual* or transgender* or transsexual* or sexual* orient*).tw. | 25554
23 | exp Socioeconomic factors/ | 370883
24 | homeless persons/ | 6085
25 | “transients and migrants”/ | 9084
26 | (Socio-demographic* or Sociodemographic* or socioeconomic* or socio-economic* or SES or sociocultural* or socio-cultural* or poverty or indigent or low-income or class or classes or disadvantaged).tw. | 578928
27 | female/ or (women* or female* or gender* or sex or sex-based).tw. | 7512980
28 | exp religion/ or religio*.tw. | 66505
29 | rural population/ or urban population/ or (rural-urban or rural or urban or inner-city).tw. | 211536
30 | “Aged, 80 and over”/ or exp Aged/ or Dental Care for Aged/ or health services for the aged/ or Middle Aged/ or Young Adult/ or (aged or aging or frail or old or older or senior* or elderly or middle-aged).tw. | 5317645
31 | health services for persons with disabilities/ or (disabilit* or disabled or handicap*).tw. | 160130
32 | mental health/ | 25017
33 | mental disorders/ | 130378
34 | Psychotic Disorders/ | 34754
35 | Schizophrenia/ | 88315
36 | Schizophrenia, catatonic/ | 549
37 | Schizophrenia, disorganized/ | 523
38 | Schizophrenia, paranoid/ | 3831
39 | Shared Paranoid Disorder/ | 290
40 | Schizoid Personality Disorder/ | 574
41 | Schizotypal Personality Disorder/ | 2346
42 | Affective disorders, psychotic/ | 2181
43 | Bipolar Disorder/ | 34398
44 | Cyclothymic Disorder/ | 548
45 | Stress disorders, traumatic/ | 533
46 | Combat Disorders/ | 2768
47 | Stress disorders, post-traumatic/ | 24281
48 | Stress disorders, traumatic, acute/ | 352
49 | (psychotic or schizotyp* or schizophren* or schizoid* or schizoaffective or bipolar or mania* or hypomania* or hypo-mania* or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe* or serious* or chronic* or persistent*) adj mental* ill*)).tw. | 194414
50 | Population groups/ | 3059
51 | Race relations/ | 2391
52 | Minority groups/ | 11512
53 | Continental Population Groups/ | 17748
54 | American Native Continental Ancestry Group/ | 409
55 | African continental ancestry group/ | 34133
56 | Asian Continental Ancestry Group/ | 44531
57 | Oceanic Ancestry Group/ | 7908
58 | African Americans/ | 47804
59 | Hispanic Americans/ | 21985
60 | Indians, north American/ | 12856
61 | Asian Americans/ | 6309
62 | exp Ethnic groups/ | 125175
63 | (Ethnic* or race* or racial* or minority or minorities or African-American* or Black or Blacks or Hispanic* or Chicano* or Chicana* or Latino* or Latina* or Hispanic* or Asian-American* or Native American* or Indian or Indians).tw. | 388894
64 | ((vulnerable adj2 population*) or subgroup* or sub-group* or subpopulation* or sub-population* or stratif*).tw. | 336981
65 | cultural competency/ or (cultural* competen* or microinsult* or microaggression*).tw. | 5885
66 | or/16-64 | 10050541
67 | exp “United States Department of Veterans Affairs”/ or exp Veterans Health/ or exp Hospitals, Federal/ or exp Veterans Disability Claims/ or exp Veterans/ or hospitals, veterans/ or gulf war/ or vietnam conflict/ or world war ii/ or afghan campaign 2001-/ or iraq war, 2003-2011/ | 27660
68 | (veteran* or VA or “Veterans Affairs” or VHA or “Veterans Health Administration” or VAMC).tw. | 42658
69 | or/67-68 | 54931
70 | and/15,66,69 | 4547
71 | (2006* or 2007* or 2008* or 2009* or 2010* or 2011* or 2012* or 2013* or 2014* or 2015* or 2016*).ed. | 9401974
72 | 70 and 71 | 2687
73 | limit 72 to english language | 2627
74 | limit 73 to (comment or editorial or letter or news) | 94
75 | 73 not 74 | 2533
76 | 75 not “visual acuity (VA)”.tw. | 2394
77 | remove duplicates from 76 | 2247

#### Ovid PsycINFO 1806 to February Week 1 2016

Date searched: 02/10/2016

1 | exp Health Disparities/ | 4969
2 | treatment barriers/ | 3119
3 | Health care services/ | 31595
4 | health care delivery/ | 18244
5 | “quality of care”/ | 10412
6 | health care utilization/ | 13133
7 | Health personnel attitudes/ | 15627
8 | (Discriminat* or Disparit* or parity or Inequal* or Unequal or equal or Inequit* or Equity or equitable or undertreat* or under-treat* or overtreat* or over-treat* or access or accessible or accessibility or bias or biases).tw. | 319804
9 | or/1-8 | 386469
10 | transgender/ | 2391
11 | homosexuality/ or “homosexuality (attitudes toward)”/ | 9473
12 | male homosexuality/ | 12005
13 | lesbianism/ | 9222
14 | bisexuality/ | 5765
15 | exp Transsexualism/ | 2660
16 | (LBG or LGBT* or lesbian* or homosexual* or gay or gays or bisexual* or transgender* or transsexual* or sexual* orient*).tw. | 37571
17 | socioeconomic status/ or income level/ or lower class/ or social class/ or disadvantaged/ or poverty/ or socioeconomic class attitudes/ or lower class attitudes/ | 45398
18 | homeless/ or homeless mentally ill/ | 5988
19 | (Socio-demographic* or Sociodemographic* or socioeconomic* or socio-economic* or SES or sociocultural* or socio-cultural* or poverty or indigent or low-income or class or classes or disadvantaged).tw. | 241258
20 | Female.po. or exp Sex Discrimination/ or (women* or female* or gender* or sex or sex-based).tw. | 1309280
21 | religion/ or exp religious beliefs/ or exp religious organizations/ or exp religious practices/ or exp religious prejudices/ or religio*.tw. | 83080
22 | exp Rural Environments/ or exp Urban Environments/ or (rural-urban or rural or urban or inner-city).tw. | 80027
23 | (“300” or “320” or “340” or “360” or “380” or “390”).po. or “aging (attitudes toward)”/ or age discrimination/ or “aged (attitudes toward)”/ or (aged or aging or frail or old or older or senior* or elderly or middle-aged).tw. | 565721
24 | disabilities/ or learning disabilities/ or multiple disabilities/ or reading disabilities/ or disability discrimination/ or “disabled (attitudes toward)”/ or (disabilit* or disabled or handicap*).tw. | 131195
25 | mental health/ | 47131
26 | mental disorders/ or chronic mental illness/ or “mental illness (attitudes toward)”/ | 74701
27 | exp psychosis/ | 99080
28 | exp schizophrenia/ | 77765
29 | schizophrenia/ or acute schizophrenia/ or catatonic schizophrenia/ or childhood schizophrenia/ or paranoid schizophrenia/ or process schizophrenia/ or “schizophrenia (disorganized type)”/ or schizophreniform disorder/ or undifferentiated schizophrenia/ | 77765
30 | schizoid personality disorder/ | 624
31 | exp Folie A Deux/ | 174
32 | exp Schizotypal Personality Disorder/ | 1323
33 | affective disorders/ | 12270
34 | bipolar disorder/ | 21866
35 | exp Cyclothymic Personality/ | 203
36 | posttraumatic stress disorder/ | 24848
37 | acute stress disorder/ | 507
38 | (psychotic or schizotyp* or schizophren* or schizoid* or schizoaffective or bipolar or mania* or hypomania* or hypo-mania* or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe* or serious* or chronic* or persistent*) adj mental* ill*)).tw. | 202517
39 | “racial and ethnic groups”/ or racism/ or “race and ethnic discrimination”/ or stereotyped attitudes/ or social discrimination/ | 32753
40 | african cultural groups/ | 1822
41 | asians/ or chinese cultural groups/ or japanese cultural groups/ or korean cultural groups/ or south asian cultural groups/ or southeast asian cultural groups/ or vietnamese cultural groups/ | 19866
42 | “latinos/latinas”/ or mexican americans/ | 23357
43 | minority groups/ or alaska natives/ or american indians/ or arabs/ or blacks/ or hawaii natives/ or inuit/ or jews/ or romanies/ | 64581
44 | pacific islanders/ or hawaii natives/ | 719
45 | indigenous populations/ or alaska natives/ or american indians/ or inuit/ | 10306
46 | (Ethnic* or race* or racial* or minority or minorities or African-American* or Black or Blacks or Hispanic* or Chicano* or Chicana* or Latino* or Latina* or Hispanic* or Asian-American* or Native American* or Indian or Indians).tw. | 223875
47 | ((vulnerable adj2 population*) or subgroup* or sub-group* or subpopulation* or sub-population* or stratif*).tw. | 57013
48 | cultural sensitivity/ or cross cultural treatment/ or cross cultural differences/ or (cultural* competen* or microinsult* or microaggression*).tw. | 54787
49 | or/10-48 | 2096947
50 | military veterans/ or (veteran* or VA or “Veterans Affairs” or VHA or “Veterans Health Administration” or VAMC).tw. | 18623
51 | and/9,49-50 | 2139
52 | (2006* or 2007* or 2008* or 2009* or 2010* or 2011* or 2012* or 2013* or 2014* or 2015* or 2016*).up. | 1868212
53 | and/51-52 | 1555
54 | limit 53 to (“column/opinion” or “comment/reply” or editorial or letter) | 62
55 | 53 not 54 | 1493

#### Ovid EBM Reviews

- Cochrane Central Register of Controlled Trials January 2016
- Cochrane Database of Systematic Reviews 2005 to February 03, 2016
- Database of Abstracts of Reviews of Effects 1st Quarter 2016
- Health Technology Assessment 1st Quarter 2016
- Date Searched: 02/11/2016

1 | (Discriminat* or Disparit* or parity or Inequal* or Unequal or equal or Inequit* or Equity or equitable or undertreat* or under-treat* or overtreat* or over-treat* or access or accessible or accessibility).tw. | 428980
2 | (LGBT* or lesbian* or homosexual* or gay or gays or bisexual* or transgender* or transsexual* or sexual* orient*).tw. | 575
3 | (Socio-demographic* or Sociodemographic* or socioeconomic* or socio-economic* or SES or sociocultural* or socio-cultural* or poverty or indigent or low-income or class or classes or disadvantaged).tw. | 25289
4 | (women* or female* or gender* or sex or sex-based).tw. | 137925
5 | religio*.tw. | 512
6 | (rural-urban or rural or urban or inner-city).tw. | 8281
7 | (aged or aging or frail or old or older or senior* or elderly or middle-aged).tw. | 92909
8 | (disabilit* or disabled or handicap*).tw. | 15908
9 | (psychotic or schizotyp* or schizophren* or schizoid* or schizoaffective or bipolar or mania* or hypomania* or hypo-mania* or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe* or serious* or chronic* or persistent*) adj mental* ill*)).tw. | 18814
10 | (Ethnic* or race* or racial* or minority or minorities or African-American* or Black or Blacks or Hispanic* or Chicano* or Chicana* or Latino* or Latina* or Hispanic* or Asian-American* or Native American* or Indian or Indians).tw. | 20288
11 | ((vulnerable adj2 population*) or subgroup* or sub-group* or subpopulation* or sub-population* or stratif*).tw. | 43614
12 | (cultural* competen* or microinsult* or microaggression*).tw. | 92
13 | or/2-12 | 269480
14 | (veteran* or VA or “Veterans Affairs” or VHA or “Veterans Health Administration” or VAMC).tw. | 4420
15 | and/1,13-14 | 1318
16 | (2006* or 2007* or 2008* or 2009* or 2010* or 2011* or 2012* or 2013* or 2014* or 2015* or 2016*).yr. | 444071
17 | 15 and 16 | 913
18 | 17 not “visual acuity (VA)”.tw. | 842
19 | limit 18 to english language [Limit not valid in CDSR,DARE; records were retained] | 826
20 | remove duplicates from 19 | 804

#### EBSCOHOST CINAHL

Date Searched: April 12, 2016

[underlined: Limits] Published Date: 20060101-20160531; English Language; Exclude MEDLINE records; Publication Type: Abstract, Book, Book Chapter, Case Study, Clinical Trial, Journal Article, Meta Analysis, Meta Synthesis, Proceedings, Randomized Controlled Trial, Review, Systematic Review; Age Groups: Adult: 19-44 years, Middle Aged: 45-64 years, Aged: 65+ years, Aged, 80 and over
# | Search Terms | Result
S64 | S14 AND S60 AND S63 | 183
S63 | S61 OR S62 | 21,073
S62 | veteran* or VA or “Veterans Affairs” or VHA or “Veterans Health Administration” or VAMC | 21,073
S61 | (MH “Hospitals, Veterans”) OR (MH “United States Department of Veterans Affairs”) OR (MH “Vietnam Veterans”) OR (MH “Veterans”) | 15,589
S60 | S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54 OR S55 OR S56 OR S57 OR S58 OR S59 | 2,152,898
S59 | (cultural* W1 competen*) or microinsult* or microaggression* | 7,869
S58 | (MH “Cultural Competence”) | 6,731
S57 | (vulnerable W2 population*) or subgroup* or sub-group* or subpopulation* or sub-population* or stratif* | 52,613
S56 | Ethnic* or race* or racial* or minority or minorities or African-American* or Black or Blacks or Hispanic* or Chicano* or Chicana* or Latino* or Latina* or Hispanic* or Asian-American* or Native American* or Indian or Indians | 137,488
S55 | (MH “Ethnic Groups+”) | 102,418
S54 | (MH “Asians”) | 15,314
S53 | (MH “Native Americans”) | 7,294
S52 | (MH “Hispanics”) | 24,005
S51 | (MH “Blacks”) | 40,786
S50 | (MH “Minority Groups”) | 8,668
S49 | (MH “Race Relations”) | 749
S48 | TX psychotic or schizotyp* or schizophren* or schizoid* or schizoaffective or bipolar or mania* or hypomania* or hypo-mania* or manic or cyclothymic or PTSD or post-traumatic stress or posttraumatic stress or ((severe* or serious* or chronic* or persistent*) W3 mental* ill*)) | 94,623
S47 | (MH “Stress Disorders, Post-Traumatic”) | 14,388
S46 | (MH “Cyclothymic Disorder”) | 97
S45 | (MH “Bipolar Disorder”) | 7,897
S44 | (MH “Affective Disorders, Psychotic”) | 498
S43 | (MH “Schizotypal Personality Disorder”) | 199
S42 | (MH “Paranoid Disorders”) | 478
S41 | (MH “Schizophrenia”) | 17,261
S40 | (MH “Psychotic Disorders”) | 7,397
S39 | (MH “Mental Disorders”) | 40,135
S38 | (MH “Mental Health”) | 19,042
S37 | disabilit* or disabled or handicap* | 117,918
S36 | (MH “Health Services for Persons with Disabilities”) | 16
S35 | aged or aging or frail or old or older or senior* or elderly or middle-aged | 740,517
S34 | (MH “Middle Age”) OR (MH “Age Specific Care”) | 663,638
S33 | (MH “Health Services for the Aged”) OR (MH “Dental Care for Aged”) OR (MH “Aged”) OR (MH “Aged, 80 and Over”) | 557,338
S32 | rural-urban or rural or urban or inner-city | 76,119
S31 | (MH “Rural Population”) OR (MH “Urban Population”) | 9,915
S30 | religio* | 17,661
S29 | (MH “Religion and Religions+”) OR (MH “Religion and Medicine”) | 31,964
S28 | women* or female* or gender* or sex or sex-based | 1,401,842
S27 | (MH “Women”) OR (MH “Women's Health Services”) OR (MH “Women's Health”) | 38,714
S26 | TX Socio-demographic* or Sociodemographic* or socioeconomic* or socio-economic* or SES or sociocultural* or socio-cultural* or poverty or indigent or low-income or class or classes or disadvantaged | 304,744
S25 | (MH “Transients and Migrants”) | 2,592
S24 | (MH “Homeless Persons”) | 3,746
S23 | (MH “Socioeconomic Factors+”) OR (MH “Poverty+”) OR (MH “Social Class+”) | 238,185
S22 | LGBT* or lesbian* or homosexual* or gay or gays or bisexual* or transgender* or transsexual* or sexual* orient* | 14,195
S21 | (MH “GLBT Persons”) | 1,996
S20 | (MH “Transsexuals”) OR (MH “Transsexualism”) | 878
S19 | (MH “Bisexuals”) OR (MH “Bisexuality”) | 1,526
S18 | (MH “Lesbians”) | 1,840
S17 | (MH “Homosexuals, Male”) | 3,332
S16 | (MH “Homosexuals”) OR (MH “Homosexuality”) | 5,515
S15 | (MH “Transgendered Persons”) | 916
S14 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 | 658,248
S13 | TX Discriminat* or Disparit* or parity or Inequal* or Unequal or equal or Inequit* or Equity or equitable or undertreat* or under-treat* or overtreat* or over-treat* or access or accessible or accessibility | 489,015
S12 | (MH “Patient Satisfaction”) | 37,275
S11 | (MH “Dentist-Patient Relations”) | 1,389
S10 | (MH “Nurse-Patient Relations”) | 22,318
S9 | (MH “Physician-Patient Relations”) | 22,780
S8 | (MH “Professional-Patient Relations”) | 23,124
S7 | (MH “Attitude of Health Personnel”) | 28,790
S6 | (MH “Quality of Health Care”) | 50,683
S5 | (MH “Health Care Delivery”) | 33,123
S4 | (MH “Health Services Needs and Demand”) | 16,847
S3 | (MH “Health Services Accessibility”) | 56,992
S2 | (MH “Health Status Disparities”) | 2,748
S1 | (MH “Healthcare Disparities”) | 3,464

#### ProQuest Sociological Abstracts

Date Searched: April 20, 2016

Set | Search | Results
S16 | S1 AND S14 AND S13 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/6790F8A6B8064F6CPQ/None?site=socabs&t:ac=RecentSearches) Limits applied (2006-2016 publication date) | 85
S15 | S1 AND S14 AND S13 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/D4757FC57E2B4419PQ/None?site=socabs&t:ac=RecentSearches) | 231 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/D4757FC57E2B4419PQ/None?site=socabs&t:ac=RecentSearches)
S14 | S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/F19ECDB16AD44731PQ/None?site=socabs&t:ac=RecentSearches) | 528,219 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/F19ECDB16AD44731PQ/None?site=socabs&t:ac=RecentSearches)
S13 | ab(veteran* OR VA OR “Veterans Affairs” OR VHA OR “Veterans Health Administration” OR VAMC) OR su(veterans) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/F20B788514B74787PQ/None?site=socabs&t:ac=RecentSearches) | 2,551 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/F20B788514B74787PQ/None?site=socabs&t:ac=RecentSearches)
S12 | ab(cultural* competen* OR microinsult* OR microaggression*) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/DAEC9C543BB4C75PQ/None?site=socabs&t:ac=RecentSearches) | 1,986 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/DAEC9C543BB4C75PQ/None?site=socabs&t:ac=RecentSearches)
S11 | ab(vulnerable population* OR subgroup* OR sub-group* OR subpopulation* OR sub-population* OR stratif*) or su(social stratification) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/2F27F1FBD6D94E68PQ/None?site=socabs&t:ac=RecentSearches) | 34,383 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/2F27F1FBD6D94E68PQ/None?site=socabs&t:ac=RecentSearches)
S10 | ab(Ethnic* OR race* OR racial* OR minority OR minorities OR African-American* OR Black OR Blacks OR Hispanic* OR Chicano* OR Chicana* OR Latino* OR Latina* OR Hispanic* OR Asian-American* OR Native American* OR Indian OR Indians) or su(American Indians or Arab Americans, or Asian Americans or Black Americans or Eskimos or Hispanic Americans or Jewish Americans or African Cultural Groups or Asian Cultural Groups or Middle Eastern Cultural Groups or Latin American Cultural Groups or North American Cultural Groups or Oceanic Cultural Groups or Race or Ethnicity) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/48324E4A68014E7BPQ/None?site=socabs&t:ac=RecentSearches) | 178,830 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/48324E4A68014E7BPQ/None?site=socabs&t:ac=RecentSearches)
S9 | ab(psychotic OR schizotyp* OR schizophren* OR schizoid* OR schizoaffective OR bipolar OR mania* OR hypomania* OR hypo-mania* OR manic OR cyclothymic OR PTSD OR post-traumatic stress OR posttraumatic stress OR severe* mental* ill* OR serious* mental* ill* OR chronic* mental* ill* OR persistent* mental* ill*) or su(mental illness or schizophrenia or psychopathology or posttraumatic stress disorder or bipolar disorders or cyclothymia) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/98A3ADD1285C487CPQ/None?site=socabs&t:ac=RecentSearches) | 9,545
S8 | ab(disabilit* OR disabled OR handicap*) or su(handicapped or physically handicapped) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/17D18A9BA8114994PQ/None?site=socabs&t:ac=RecentSearches) | 10,467 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/17D18A9BA8114994PQ/None?site=socabs&t:ac=RecentSearches)
S7 | ab(aged OR aging OR frail OR old OR older OR senior* OR elderly OR middle-aged) or su(aging or elderly or middle aged adults) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/49B7358BAEDC4DD3PQ/None?site=socabs&t:ac=RecentSearches) | 71,149 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/49B7358BAEDC4DD3PQ/None?site=socabs&t:ac=RecentSearches)
S6 | ab(rural-urban OR rural OR urban OR inner-city)or su(rural urban differences or urban rural differences or rural areas or urban areas) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/EA6DA3E32AFB40D5PQ/None?site=socabs&t:ac=RecentSearches) | 56,206 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/EA6DA3E32AFB40D5PQ/None?site=socabs&t:ac=RecentSearches)
S5 | ab(religio*) or su(religions or Religious Cultural Groups) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/7A8AD796909440AFPQ/None?site=socabs&t:ac=RecentSearches) | 77,095 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/7A8AD796909440AFPQ/None?site=socabs&t:ac=RecentSearches)
S4 | ab(women* OR female* OR gender* OR sex OR sex-based) or su(womens health care or working women or females or sexism or sex role attitudes or sexual inequality) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/5156148F8174829PQ/None?site=socabs&t:ac=RecentSearches) | 180,772 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/5156148F8174829PQ/None?site=socabs&t:ac=RecentSearches)
S3 | ab(Socio-demographic* OR Sociodemographic* OR socioeconomic* OR socio-economic* OR SES OR sociocultural* OR socio-cultural* OR poverty OR indigent OR low-income OR class OR classes OR disadvantaged) or su(socioeconomic factors or social background or social factors or sociocultural factors or sociodemographic factors or socioeconomic status or poverty or rural poverty or rural poor or urban poverty or urban poor or income inequality or social inequality or social class) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/CD26E5EF8D7E46E5PQ/None?site=socabs&t:ac=RecentSearches) | 165,056 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/CD26E5EF8D7E46E5PQ/None?site=socabs&t:ac=RecentSearches)
S2 | ab(LGBT* OR lesbian* OR homosexual* OR gay OR gays OR bisexual* OR transgender* OR transsexual* OR sexual* orient*) or su(Lesbianism or bisexuality or homosexuality or transsexuality or homophobia) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/F81D248CDEE441DDPQ/None?site=socabs&t:ac=RecentSearches) | 15,518 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/F81D248CDEE441DDPQ/None?site=socabs&t:ac=RecentSearches)
S1 | ab(Discriminat* OR Disparit* OR parity OR Inequal* OR Unequal OR equal OR Inequit* OR Equity OR equitable OR undertreat* OR under-treat* OR overtreat* OR over-treat* OR access OR accessible OR accessibility) or su(discrimination or racial discrimination or equality or inequality or access) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/2180DF8B18AF4514PQ/None?site=socabs&t:ac=RecentSearches) | 101,521 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/2180DF8B18AF4514PQ/None?site=socabs&t:ac=RecentSearches)

#### ProQuest Social Services Abstracts

Date Searched: April 21, 2016

Set | Search | Results
S16 | S1 AND S14 AND S13 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/AFA5BCE791F34188PQ/None?site=socialservices&t:ac=RecentSearches) Limits applied (2006-2016) | 45 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/AFA5BCE791F34188PQ/None?site=socialservices&t:ac=RecentSearches)
S15 | S1 AND S14 AND S13 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/AEBAA9E22C884678PQ/None?site=socialservices&t:ac=RecentSearches) | 78
S14 | S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/5C4AE19472A54292PQ/None?site=socialservices&t:ac=RecentSearches) | 115,167 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/5C4AE19472A54292PQ/None?site=socialservices&t:ac=RecentSearches)
S13 | ab(veteran* OR VA OR “Veterans Affairs” OR VHA OR “Veterans Health Administration” OR VAMC) OR su(veterans) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/AA6A964FF42F480CPQ/None?site=socialservices&t:ac=RecentSearches) | 1,460 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/AA6A964FF42F480CPQ/None?site=socialservices&t:ac=RecentSearches)
S12 | ab(cultural* competen* OR microinsult* OR microaggression*) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/76CD4CC85C9A4634PQ/None?site=socialservices&t:ac=RecentSearches) | 1,319 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/76CD4CC85C9A4634PQ/None?site=socialservices&t:ac=RecentSearches)
S11 | ab(vulnerable population* OR subgroup* OR sub-group* OR subpopulation* OR sub-population* OR stratif*) or su(social stratification) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/D35B054E12F64D47PQ/None?site=socialservices&t:ac=RecentSearches) | 3,826 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/D35B054E12F64D47PQ/None?site=socialservices&t:ac=RecentSearches)
S10 | ab(Ethnic* OR race* OR racial* OR minority OR minorities OR African-American* OR Black OR Blacks OR Hispanic* OR Chicano* OR Chicana* OR Latino* OR Latina* OR Hispanic* OR Asian-American* OR Native American* OR Indian OR Indians) or su(American Indians or Arab Americans, or Asian Americans or Black Americans or Eskimos or Hispanic Americans or Jewish Americans or African Cultural Groups or Asian Cultural Groups or Middle Eastern Cultural Groups or Latin American Cultural Groups or North American Cultural Groups or Oceanic Cultural Groups or Race or Ethnicity) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/24588DCD75044B02PQ/None?site=socialservices&t:ac=RecentSearches) | 26,249 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/24588DCD75044B02PQ/None?site=socialservices&t:ac=RecentSearches)
S9 | ab(psychotic OR schizotyp* OR schizophren* OR schizoid* OR schizoaffective OR bipolar OR mania* OR hypomania* OR hypo-mania* OR manic OR cyclothymic OR PTSD OR post-traumatic stress OR posttraumatic stress OR severe* mental* ill* OR serious* mental* ill* OR chronic* mental* ill* OR persistent* mental* ill*) or su(mental illness or schizophrenia or psychopathology or posttraumatic stress disorder or bipolar disorders or cyclothymia) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/E95EB47D9D9E4AB9PQ/None?site=socialservices&t:ac=RecentSearches) | 9,431 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/E95EB47D9D9E4AB9PQ/None?site=socialservices&t:ac=RecentSearches)
S8 | ab(disabilit* OR disabled OR handicap*) or su(handicapped or physically handicapped) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/EE13FB9504CF4AAFPQ/None?site=socialservices&t:ac=RecentSearches) | 8,327 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/EE13FB9504CF4AAFPQ/None?site=socialservices&t:ac=RecentSearches)
S7 | ab(aged OR aging OR frail OR old OR older OR senior* OR elderly OR middle-aged) or su(aging or elderly or middle aged adults) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/7622D6295C7C4D89PQ/None?site=socialservices&t:ac=RecentSearches) | 30,467 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/7622D6295C7C4D89PQ/None?site=socialservices&t:ac=RecentSearches)
S6 | ab(rural-urban OR rural OR urban OR inner-city)or su(rural urban differences or urban rural differences or rural areas or urban areas) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/84417BC9D27740EAPQ/None?site=socialservices&t:ac=RecentSearches) | 12,811 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/84417BC9D27740EAPQ/None?site=socialservices&t:ac=RecentSearches)
S5 | ab(religio*) or su(religions or Religious Cultural Groups) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/5B9B212585BA40C7PQ/None?site=socialservices&t:ac=RecentSearches) | 4,550 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/5B9B212585BA40C7PQ/None?site=socialservices&t:ac=RecentSearches)
S4 | ab(women* OR female* OR gender* OR sex OR sex-based) or su(womens health care or working women or females or sexism or sex role attitudes or sexual inequality) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/DA3892D1E7F2430APQ/None?site=socialservices&t:ac=RecentSearches) | 42,835 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/DA3892D1E7F2430APQ/None?site=socialservices&t:ac=RecentSearches)
S3 | ab(Socio-demographic* OR Sociodemographic* OR socioeconomic* OR socio-economic* OR SES OR sociocultural* OR socio-cultural* OR poverty OR indigent OR low-income OR class OR classes OR disadvantaged) or su(socioeconomic factors or social background or social factors or sociocultural factors or sociodemographic factors or socioeconomic status or poverty or rural poverty or rural poor or urban poverty or urban poor or income inequality or social inequality or social class) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/6338C2B8B1CD440FPQ/None?site=socialservices&t:ac=RecentSearches) | 34,229 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/6338C2B8B1CD440FPQ/None?site=socialservices&t:ac=RecentSearches)
S2 | ab(LGBT* OR lesbian* OR homosexual* OR gay OR gays OR bisexual* OR transgender* OR transsexual* OR sexual* orient*) or su(Lesbianism or bisexuality or homosexuality or transsexuality or homophobia) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/29C44F57DE9E4FBAPQ/None?site=socialservices&t:ac=RecentSearches) | 5,254 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/29C44F57DE9E4FBAPQ/None?site=socialservices&t:ac=RecentSearches)
S1 | ab(Discriminat* OR Disparit* OR parity OR Inequal* OR Unequal OR equal OR Inequit* OR Equity OR equitable OR undertreat* OR under-treat* OR overtreat* OR over-treat* OR access OR accessible OR accessibility) or su(discrimination or racism or bias or prejudice or equality or inequality or access) (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink:rerunsearch/B0149E30CE734AE0PQ/None?site=socialservices&t:ac=RecentSearches) | 23,972 (http://search.proquest.com.proxy.lib.pdx.edu/recentsearches.recentsearchtabview.recentsearchesgridview.scrolledrecentsearchlist.checkdbssearchlink_0:rerunsearch/B0149E30CE734AE0PQ/None?site=socialservices&t:ac=RecentSearches)

#### ClinicalTrials.gov

Date Searched: April 22, 2016

(veteran* OR VA OR Veterans Affairs OR VHA OR Veterans Health Administration OR VAMC ) AND ( discrimination OR discriminate OR discriminated OR disparity OR disparities OR parity OR Inequality OR inequalities OR unequal OR unequally OR inequity OR inequities OR equity OR equitable OR accessible OR accessibility OR prejudice OR prejudicial OR homophobia OR homophobic OR racism OR racist ) \| Adult, Senior \| received from 01/01/2006 to 04/22/2016 = 96 results