# REFERENCES

1 Chang C, Jackson SS, Bullman TA, Cobbs EL. Impact of a home-based primary care program in an urban Veterans Affairs medical center. J Am Med Dir Assoc. Feb. 2009;10(2):133-137. [pmid: 19187882].
2 Dang S, Remon N, Harris J, et al. Care coordination assisted by technology for multiethnic caregivers of persons with dementia: a pilot clinical demonstration project on care-giver burden and depression. J Telemed Telecare. 2008;14(8):443-447. [pmid: 19047456].
3 Shore JH, Brooks E, Savin D, Orton H, Grigsby J, Manson SM. Acceptability of telepsychiatry in American Indians. Telemed J E Health. Jun. 2008;14(5):461-466. [pmid: 18578681].
4 Dang S, Ma F, Nedd N, Florez H, Aguilar E, Roos BA. Care coordination and telemedicine improves glycaemic control in ethnically diverse veterans with diabetes. J Telemed Telecare. 2007;13(5):263-267. [pmid: 17697515].
5 Weng HH, Kaplan RM, Boscardin WJ, et al. Development of a decision aid to address racial disparities in utilization of knee replacement surgery. Arthritis Rheum. May. 15. 2007;57(4):568-575. [pmid: 17471558].
6 Hawthorne K, Robles Y, Cannings-John R, Edwards AG. Culturally appropriate health education for Type 2 diabetes in ethnic minority groups: a systematic and narrative review of randomized controlled trials. Diabet Med. Jun. 2010;27(6):613-623. [pmid: 20546277].
7 Hawthorne K, Robles Y, Cannings-John R, Edwards AG. Culturally appropriate health education for type 2 diabetes mellitus in ethnic minority groups. Cochrane Database Syst Rev. 2008;(3):CD006424. [pmid: 18646153].
8 Peek ME, Cargill A, Huang ES. Diabetes health disparities: a systematic review of health care interventions. Med Care Res Rev. Oct. 2007;64(5 Suppl):101S-156S. [pmid: 17881626].
9 Saxena S, Misra T, Car J, Netuveli G, Smith R, Majeed A. Systematic review of primary healthcare interventions to improve diabetes outcomes in minority ethnic groups. J Ambul Care Manage. Jul-Sep. 2007;30(3):218-230. [pmid: 17581434].
10 Norris SL, Chowdhury FM, Van Le K, et al. Effectiveness of community health workers in the care of persons with diabetes. Diabet Med. May. 2006;23(5):544-556. [pmid: 16681564].
11 Sarkisian CA, Brown AF, Norris KC, Wintz RL, Mangione CM. A systematic review of diabetes self-care interventions for older, African American, or Latino adults. Diabetes Educ. May-Jun. 2003;29(3):467-479. [pmid: 12861963].
12 McIlvane JM, Baker TA, Mingo CA, Haley WE. Are behavioral interventions for arthritis effective with minorities? Addressing racial and ethnic diversity in disability and rehabilitation. Arthritis Rheum. Oct. 15. 2008;59(10):1512-1518. [pmid: 18821638].
13 Ettinger WH Jr, Burns R, Messier SP, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). JAMA. Jan. 1. 1997;277(1):25-31. [pmid: 8980206].
14 Penninx BW, Messier SP, Rejeski WJ, et al. Physical exercise and the prevention of disability in activities of daily living in older persons with osteoarthritis. Archives of Internal Medicine. Oct. 22. 2001;161(19):2309-2316. [pmid: 11606146].
15 Corcoran J, Dattalo P, Crowley M. Interventions to increase mammography rates among U.S. Latinas: a systematic review. J Womens Health (Larchmt). Jul. 2010;19(7):1281-1288. [pmid: 20575619].
16 Martinez-Donate AP. Using lay health advisors to promote breast and cervical cancer screening among Latinas: a review. WMJ. Aug. 2009;108(5):259-262. [pmid: 19743759].
17 Han HR, Lee JE, Kim J, Hedlin HK, Song H, Kim MT. A meta-analysis of interventions to promote mammography among ethnic minority women. Nurs Res. Jul-Aug. 2009;58(4):246-254. [pmid: 19609176].
18 Masi CM, Blackman DJ, Peek ME. Interventions to enhance breast cancer screening, diagnosis, and treatment among racial and ethnic minority women. Med Care Res Rev. Oct. 2007;64(5 Suppl):195S-242S. [pmid: 17881627].
19 O'Malley AS, Gonzalez RM, Sheppard VB, Huerta E, Mandelblatt J. Primary care cancer control interventions including Latinos: a review. Am J Prev Med. Oct. 2003;25(3):264-271. [pmid: 14507536].
20 Han HR, Kim J, Lee JE, et al. Interventions that increase use of Pap tests among ethnic minority women: a meta-analysis. Psychooncology. Apr. 29. 2010.
21 Powe BD, Faulkenberry R, Harmond L. A review of intervention studies that seek to increase colorectal cancer screening among African-Americans. Am J Health Promot. Nov-Dec. 2010;25(2):92-99. [pmid: 21039289].
22 Morrow JB, Dallo FJ, Julka M. Community-Based Colorectal Cancer Screening Trials with Multi-Ethnic Groups: A Systematic Review. J Community Health. Mar. 12. 2010.
23 Webb MS. Treating tobacco dependence among African Americans: a meta-analytic review. Health Psychol. May. 2008;27(3 Suppl):S271-282. [pmid: 18979980].
24 Webb MS, Rodriguez-Esquivel D, Baker EA. Smoking cessation interventions among Hispanics in the United States: A systematic review and mini meta-analysis. Am J Health Promot. Nov-Dec. 2010;25(2):109-118. [pmid: 21039291].
25 Davis AM, Vinci LM, Okwuosa TM, Chase AR, Huang ES. Cardiovascular health disparities: a systematic review of health care interventions. Med Care Res Rev. Oct. 2007;64(5 Suppl):29S-100S. [pmid: 17881625].
26 Whitt-Glover MC, Kumanyika SK. Systematic review of interventions to increase physical activity and physical fitness in African-Americans. Am J Health Promot. Jul-Aug. 2009;23(6):S33-56. [pmid: 19601486].
27 Osei-Assibey G, Kyrou I, Adi Y, Kumar S, Matyka K. Dietary and lifestyle interventions for weight management in adults from minority ethnic/non-White groups: a systematic review. Obes Rev. Jan. 6. 2010.
28 Eyles HC, Mhurchu CN. Does tailoring make a difference? A systematic review of the long-term effectiveness of tailored nutrition education for adults. Nutr Rev. Aug. 2009;67(8):464-480. [pmid: 19674343].
29 Perez-Escamilla R, Hromi-Fiedler A, Vega-Lopez S, Bermudez-Millan A, Segura-Perez S. Impact of peer nutrition education on dietary behaviors and health outcomes among Latinos: a systematic literature review. J Nutr Educ Behav. Jul-Aug. 2008;40(4):208-225. [pmid: 18565462].
30 Crook ED, Bryan NB, Hanks R, et al. A review of interventions to reduce health disparities in cardiovascular disease in African Americans. Ethn Dis. Spring. 2009;19(2):204-208. [pmid: 19537234].
31 Mau MK, Sinclair K, Saito EP, Baumhofer KN, Kaholokula JK. Cardiometabolic health disparities in native Hawaiians and other Pacific Islanders. Epidemiol Rev. 2009;31:113-129. [pmid: 19531765].
32 Crepaz N, Marshall KJ, Aupont LW, et al. The efficacy of HIV/STI behavioral interventions for African American females in the United States: a meta-analysis. Am J Public Health. Nov. 2009;99(11):2069-2078. [pmid: 19762676].
33 Crepaz N, Horn AK, Rama SM, et al. The efficacy of behavioral interventions in reducing HIV risk sex behaviors and incident sexually transmitted disease in black and Hispanic sexually transmitted disease clinic patients in the United States: a meta-analytic review. Sex Transm Dis. Jun. 2007;34(6):319-332. [pmid: 17038965].
34 Johnson BT, Scott-Sheldon LA, Smoak ND, Lacroix JM, Anderson JR, Carey MP. Behavioral interventions for African Americans to reduce sexual risk of HIV: a meta-analysis of randomized controlled trials. J Acquir Immune Defic Syndr. Aug. 1. 2009;51(4):492-501. [pmid: 19436218].
35 Herbst JH, Kay LS, Passin WF, et al. A systematic review and meta-analysis of behavioral interventions to reduce HIV risk behaviors of Hispanics in the United States and Puerto Rico. AIDS Behav. Jan. 2007;11(1):25-47. [pmid: 16917668].
36 Van Voorhees BW, Walters AE, Prochaska M, Quinn MT. Reducing health disparities in depressive disorders outcomes between non-Hispanic Whites and ethnic minorities: a call for pragmatic strategies over the life course. Med Care Res Rev. Oct. 2007;64(5 Suppl):157S-194S. [pmid: 17766647].
37 Ward EC. Examining differential treatment effects for depression in racial and ethnic minority women: a qualitative systematic review. J Natl Med Assoc. Mar. 2007;99(3):265-274. [pmid: 17393951].
38 Lie DA, Lee-Rey E, Gomez A, Bereknyei S, Braddock CH 3rd. Does Cultural Competency Training of Health Professionals Improve Patient Outcomes? A Systematic Review and Proposed Algorithm for Future Research. J Gen Intern Med. Oct. 16. 2010.
39 Bhui K, Warfa N, Edonya P, McKenzie K, Bhugra D. Cultural competence in mental health care: a review of model evaluations. BMC Health Serv Res. 2007;7:15. [pmid: 17266765].
40 Beach MC, Gary TL, Price EG, et al. Improving health care quality for racial/ethnic minorities: a systematic review of the best evidence regarding provider and organization interventions. BMC Public Health. 2006;6:104. [pmid: 16635262].
41 Beach MC, Price EG, Gary TL, et al. Cultural competence: a systematic review of health care provider educational interventions. Med Care. Apr. 2005;43(4):356-373. [pmid: 15778639].
42 Anderson LM, Scrimshaw SC, Fullilove MT, Fielding JE, Normand J, Task Force on Community Preventive S. Culturally competent healthcare systems. A systematic review. Am J Prev Med. Apr. 2003;24(3 Suppl):68-79. [pmid: 12668199].
43 Perry E, Swartz J, Brown S, et al. Peer mentoring: a culturally sensitive approach to end-of-life planning for long-term dialysis patients. American Journal of Kidney Diseases. Jul. 2005;46(1):111-119. [pmid: 15983964].
44 Sequist TD, Fitzmaurice GM, Marshall R, et al. Cultural competency training and performance reports to improve diabetes care for black patients: a cluster randomized, controlled trial. Annals of Internal Medicine. Jan. 5. 2010;152(1):40-46. [pmid: 20048271].
45 Kilbourne AM, Switzer G, Hyman K, et al. Advancing health disparities research within the health care system: a conceptual framework. American Journal of Public Health. Dec. 2006;96(12):2113-2121. [pmid: 17077411].
46 Fine MJ, Ibrahim SA, Thomas SB, Fine MJ, Ibrahim SA, Thomas SB. The role of race and genetics in health disparities research. American Journal of Public Health. Dec. 2005;95(12):2125-2128. [pmid: 16257933].
47 Wong MD, Shapiro MF, Boscardin WJ, et al. Contribution of major diseases to disparities in mortality. New England Journal of Medicine. Nov. 14. 2002;347(20):1585-1592. [pmid: 12432046].
48 Cooper R, Cutler J, Desvigne-Nickens P, et al. Trends and disparities in coronary heart disease, stroke, and other cardiovascular diseases in the United States: findings of the national conference on cardiovascular disease prevention. Circulation. Dec. 19. 2000;102(25):3137-3147. [pmid: 11120707].
49 Hayward M, Miles T, Crimmins E, Yang Y. The significance of socioeconomic status in explaining the racial gap in chronic health conditions. American Sociological Review. 2000;65(6):910-930.
50 Saha S, Freeman M, Toure J, Tippens KM, Weeks C, Ibrahim S. Racial and ethnic disparities in the VA health care system: a systematic review. J Gen Intern Med. May. 2008;23(5):654-671. [pmid: 18301951].
51 Gehlert S, Sohmer D, Sacks T, et al. Targeting health disparities: a model linking upstream determinants to downstream interventions. Health Affairs. Mar-Apr. 2008;27(2):339-349. [pmid: 18332488].
52 Gruen RL, Pearson SD, Brennan TA, Gruen RL, Pearson SD, Brennan TA. Physician-citizens--public roles and professional obligations. JAMA. Jan. 7. 2004;291(1):94-98. [pmid: 14709581].
53 Thomas S, Crouse Q, Butler J, Fryer C, Garza M. Toward a fourth generation of disparities research to acheive health equity. Annual Review of Public Health. 2011;32:309-416.
54 Trivedi A, Grebla R, Wright S, Washington D. Despite improved quality of care in the Veterans Affairs health system, racial disparity persists for important clinical outcomes. Health Affairs. 2011;30(4):707-715. [pmid: 21471492].