# METHODS

## TOPIC DEVELOPMENT

The review was requested by the director for the Equity Portfolio of the VA HSR&D and commissioned by the Department of Veterans Affairs Evidence-based Synthesis Program. We relied on individual topic expertise to form the technical expert panel for guiding topic development and reviewing drafts of the report. The objective of this report is to review the evidence that addresses the following key questions:

Key Question #1 What is the state of research on interventions to reduce race/ethnic disparities or to improve health and health care in minority populations within VA health care settings?
Key Question #2 What are the results of interventions (within and outside the VA) to reduce race/ethnic disparities or to improve health and health care in minority populations?

We used the following methods to address these questions:

1. Primary literature review of studies with the following characteristics:
  - Patients: any VA patient population
  - Intervention: any intervention primarily designed to reduce disparities or improve quality of care or outcomes for minority populations
  - Comparator: studies comparing minority to non-minority Veterans as well as studies focusing on outcomes for a targeted minority group of Veterans
  - Outcomes: no intention to limit by outcome
  - Timing: any length of follow-up
  - Setting: VA, inpatient or outpatient
2. Review of systematic reviews and meta-analyses of race/ethnic disparities interventions conducted in VA and non-VA settings.

In addition, discuss the utility of categorizing existing disparities research according to the kinds of populations included in the studies as well as by intervention type to provide an organizing language for the interventions literature.

- Two categories to describe included study populations:
  ◦ Single-race or minority-only populations: examined the effect of interventions within a group known to receive lower quality care, or have poorer outcomes, than the majority white population. Effectiveness documented in such studies provides only indirect evidence that the studied intervention will reduce disparities.
  ◦ Comparative: included both minority and majority populations and compare measures in both groups before and after the intervention. Such studies provide direct evidence of an intervention's capacity to reduce disparities.
- Two categories for intervention types:
  ◦ Generic interventions: applied without consideration of group specific needs or preferences. Many of these interventions involved quality improvement efforts or care standardization testing the premise that deficits in care for minority groups might be reduced if care was applied similarly for everyone.
  ◦ Tailored interventions: described efforts to address barriers specific to a minority group. Many of these interventions involved specially designed educational materials crafted with specific minority groups in mind (e.g., lessons that address knowledge and health beliefs of minority populations), or community health workers that addressed the special needs of minority patients within their own communities. Community health workers were typically members of those minority communities and therefore understood the context and culture of the population served.

## SEARCH STRATEGY

We conducted a search for recent primary intervention studies of VA patients in MEDLINE^®^ (PubMed^®^) (2006 through August 2010) using the search strategy developed for the 2007 VA ESP report on health disparities (Appendix A). We also conducted a follow-up search for recently published studies by investigators identified in the 2007 report because they were conducting pending intervention work at the time of that report. Finally, we conducted a search for systematic reviews of intervention studies that are not limited to VA patients in MEDLINE^®^ (PubMed^®^), the Cochrane Database of Systematic Reviews (OVID), and PsycINFO^®^ (OVID) (database inception through November 2010). We obtained additional articles from reference lists of pertinent studies, and through reviewer feedback following review of the initial draft of this report. All citations were imported into an electronic database (EndNote X2).

## STUDY SELECTION, QUALITY ASSESSMENT, AND DATA ABSTRACTION

Two reviewers assessed the titles and abstracts identified by the literature search for relevance to the key questions. Potentially relevant full-text articles were retrieved for further review. Two reviewers independently reviewed the articles for inclusion, and discordant results were resolved through discussion and input from a third reviewer. We included individual studies evaluating the effects of an intervention within or between racial/ethnic groups in VA patients. We relied on systematic reviews and meta-analyses of intervention studies conducted outside the VA setting (inclusion/exclusion criteria provided in Appendix B). We excluded poor quality reviews as defined by previously developed criteria (Appendix C). We also excluded reviews of interventions that were not likely to be applicable to VA settings (i.e., studies focused on reducing financial barriers to access).

From each study, we abstracted information on clinical topic, study methodology, population characteristics including race/ethnicity, types of interventions studied, search dates and number of studies included for systematic reviews.

We dual-reviewed each study for quality and data abstraction. Disagreements were resolved through discussion, and a third investigator was consulted when needed to reach consensus.

## DATA SYNTHESIS

We examined intervention studies of both primary studies of VA populations, and systematic reviews conducted in settings not limited to the VA. We organized the literature addressing Key Question #1 and Key Question #2 according to clinical or substantive topic area in the Results section including: diabetes mellitus, arthritis and pain management, preventive and ambulatory care, cardiovascular disease, human immunodeficiency virus/auto immune deficiency syndrome (HIV/AIDS), mental health, and cross-cutting interventions.

We developed an abstraction form in order to extract data from included primary studies and systematic reviews. Our syntheses of systematic reviews were qualitative in nature. Because we engaged in reviews of systematic reviews, we relied on the conclusions and syntheses from review authors to a large extent. We gave higher consideration to reviews of good quality, as determined by the quality criteria detailed in Appendix C.

## PEER REVIEW

A draft version of this report was sent to the technical expert panel and additional peer reviewers. Their comments and our responses are included in Appendix E.