# EVIDENCE TABLE

Author, Year, EN ID | Clinical topic | Population | Setting | Single-race (included only minority study participants) | Comparative (included minority and majority participants with pre and post intervention comparison) | Mostly generic or tailored interventions? | Study methodology (e.g., systematic review, metaanalysis) | Study period/search dates | Number and hierarchy of studies included | Intervention types (i.e., community health workers)
Primary Studies
Chang, 2009^1^ | Preventive | Veterans n=183 patients 71% black, 29% white | Urban VAMC (Washington DC) | No | Yes. Multiple groups, but do not analyze pre-post by race | Generic | Primary article; retrospective chart review of HBPC enrollees. Pre-post enrollment (no control) | Patients enrolled for at least 6 months during the period of January 2001-December 2002 | n/a | Multiprofessional home-based primary care (HBPC) team: medical director, nurse practitioners, registered nurses, social workers, pharmacists, registered dietician, dental hygienist and program director.
Dang, 2007^4^ | Preventive | Veterans age 60 or older n=41 patients n=21 white (51%) n=14 black (34%) n=6 Hispanic (15%) | Urban VAMC (Miami) | No | Yes | Generic | Primary study (pre-post no control group) | Patients enrolled for at least 9 months from May 2000-January 2002 | n/a | Care coordination: 2 care coordinators (nurse pract, licensed clin social worker), secretary and geriatrician (oversight) Telemedicine: telephone-based in-home messaging device for patient monitoring. Patients input blood sugar levels and answer educational questions. Data transmitted to messaging center, stratified into high/med/low risk for care coordinators following morning.
Dang, 2008^2^ | Mental health | Veterans with dementia (MMSE < 25) and live-in caregivers; white = 72, AA = 32, Hispanic = 9. | Homes of caregivers/recipients. | No | Yes. Multiple groups, but do not analyze pre-post by race | Generic | Primary article; pre-post with no control group | n/a | n/a | Screen telephones and support by care coordinators.
Shore, 2008^3^ | Mental health | American Indian Vietnam Veterans | In person and telephone interviews | Yes | No | Tailored | Primary article; tests of mean differences, comparisons of kappas. | n/a | n/a | Telephone and in person interviews to test the feasibility of SCID in this population/setting
Weng, 2007^5^ | Pain/arthritis | African American and white male Veterans n=102 patients at baseline (n=54 black and n=48 white) n=64 completed followup questionnaire (n=33 black, n=31 white) | Urban VAMC (Greater Los Angeles) | No | Yes | Tailored | Primary study (pre-post no control group) | n/a | n/a | Educational videotape and tailored total knee replacement (TKR) decision aid
Systematic Reviews
Anderson, 2003^40^ | Cross-cutting | Minorities only | All medical settings | Yes. Most included studies are single-race. | No | Tailored | Systematic review | 1965-2001 | 6 RCTs | Clinician bias: recruitment/retention of diverse staff, interpreter services, cultural competence training, ed materials, culturally specific health care settings.
Beach, 2005^39^ | Cross-cutting | Health professionals and ethnic minority patients | n/a | Yes. Most included studies are single-race. | No | Tailored | Systematic review | 1980 through 2/2003 | 2 RCTs, 12 controlled, 20 pre-post. | Training programs varying in lengths generally effective in improving certain aspects of provider characteristics.
Beach, 2006^38^ | Preventive | Physicians, nurses and medical assistants and emergency medical personnel. | Hospital outpatient Community health center Group practice Community care | Yes. Some included studies are single-race. | Yes. Most included studies are comparative. | Tailored | Systematic review | 1980-June 2003 | n=27 RCT n=20 CCT n=7 | Tracking/reminder systems, bypassing the physician, safe times questionnaires for pts, remote simultaneous translation
Corcoran, 2010^13^ | Preventive | Latinas in the US | Community (6) and clinic (3) settings in California, Texas, New Mexico, Colorado and Washington | Yes. All included studies are single-race. | No | Tailored | Meta-analysis | ended January 2009 | n=9 Quasi-experimental n=6 RCT n=3 | Lay-health advisor (promotoras), printed mailings, educational groups, television campaigns, access-enhancing (1 study)
Crepaz, 2007^31^ | HIV/AIDS | Black and Hispanic STD Clinic Patients | STD Clinics | No | Yes. Some included studies are comparative, but do not analyze pre-post by race. | Tailored | Meta-analysis | 1998-june 2005 | 18 RCTs | Intervention delivered by health educator/counselor
Crepaz, 2009^30^ | HIV/AIDS | African American Females | Health Care and Community Settings | Yes | Yes. Some included studies are comparative, but do not analyze pre-post by race. | Tailored | Meta-analysis | January 1988 to June 2007 | 37 individual and groups level intervention studies and 4 community level intervention studies. | Patient activation
Crook, 2009^28^ | CVD | African-Americans | Ambulatory care and community settings | Yes | No | Generic | Systematic review | 1996 - 2006 | NR | Counseling/education for behavior change; screening; changes in delivery system; exercise, stress reduction, dietary modification
Davis, 2007^27^ | CVD | Minorities and whites | Community and health care settings. Interventions had to be connected to health care organizations. | Yes. Most included studies are single-race. | Yes. Some included studies are comparative, but do not analyze pre-post by race. | Generic | Systematic review | 1995 - 2006 | Overall: 52 RCT, 8 pre-post, 2 non-randomized controlled clinical trials | Provider and care delivery interventions (e.g., patient outreach, clinic reorganization, interventions with nurses alone or with community health workers included); patient and family interventions
Eyles, 2009 25 | Preventive | Health or mixed-health status adults aged 18 to 85+ | Non-face-to-face methods of contacting participants. Of the US studies, 6 were conducted in community settings, 4 were conducted in clinical/health care settings and 2 did not report recruitment activities. | Yes. One included study was single-race. | Yes | Tailored | Meta-analysis (and narrative summaries) | January 1990-December 2007 | n=16 All studies were RCT or quasi-RCT All studies included experimental group that received tailored nutrition education and control group with either generic and/or no nutrition education. 11 were conducted in the US, 1 was conducted in US and Canada | Tailored nutrition education included print, email or other non-face-to-face format (excluded studies that used face-to-face delivery methods)
Han, 2009^15^ | Preventive | Adult Asian/PI, African American, Hispanic and white women | n=19 in community settings n=4 in health care settings | Yes. Most included studies are single-race. | Yes. Some included studies are comparative, but do not analyze pre-post by race. | Tailored | Meta-analysis | September 2000 - August 2008 | n=23 RCT n=14 All studies were experimental or quasi-experimental design. Evidence tables offered as supplemental online content | directed print materials, peer/lay health advisor education and support, telephone counseling.
Han, 2010^18^ | Preventive | Adult women. N=4 predominantly African American; N=3 mostly Hispanic; N=8 mostly Asian; N=1 mostly Native American; N=2 combination of Hispanic and African American | n=5 health care settings n=13 community settings | Yes. Most included studies are single-race. | Yes | Generic | Meta-analysis | 1984-April 2009 | n=18 RCT n=9 Quasi-experimental non randomized n=9 | 1. individual-directed (in-person and phone counseling); 2. Access-enhancing (reduced cost, mobile vans); 3. Peer-navigator (lay health advisors); 4. Community education (small group workshops/seminars); 5. Mass media (tv, newspaper, radio campaigns)
Hawthorne, 2010^6^ Hawthorne 2008;^7^ | Diabetes | All included studies were conducted in single-race groups. Some populations don't apply to US (e.g. South Asian British). | Group and individual sessions in clinics, community medical centers, homes of participants, hospital and GP practices. Type of HE provider ranged from peer leaders, certified DM educators, bilingual nurse, CHW, podiatrist, dietician, exercise physiotherapist. | Yes. All included studies were conducted in single-race groups. | No | Tailored | Systematic review and meta-analysis | 1966 or inception thru 2007 | 12 RCTs | Culturally appropriate health education (group sessions in the majority of included studies) defined as HE tailored to the cultural or religious beliefs and linguistic and literacy skills of the community being studied.
Herbst, 2007^33^ | HIV/AIDS | Hispanics | Health/drug treatment clinics, schools, community based organizations, and farm worker campsites | Yes | No | Tailored | Meta-analysis | 1988-2006 | 20 studies included in meta-analysis | Variety of implementation methods from fotonovela to health educator/outreach worker
Johnson, 2009^32^ | HIV/AIDS | African Americans | Community and clinical settings | Yes | Yes. Most included studies are comparative, but do not analyze pre-post by race. | Tailored | Meta-analaysis | 1981-2006 | 78 RCTs | Health education
Lie, 2010^36^ | Cross-cutting | All patient populations | All medical settings | Yes. One included study was single-race. | No | Tailored | Systematic review | 1/1990-3/2010 | 2 quasi-randomized, 2 cluster randomized, 3 pre-post. | Cultural competence curricula
Martinez-Donate, 2009 14 | Preventive | Latinas and non-Latinas in the US | Community setting; majority of included studies in the West and Southwest US | No | Yes | Generic | Systematic review | Through August 2008 | N=14 RCT N=2 CCT N=6 | Lay health advisors (education, phone counseling, media campaign, social support, community events, mobile screening)
Masi, 2007^16^ | Preventive | Minority and white female patients (mostly African American and Hispanic), providers | Health care settings | Yes. A few included studies are single-race. | Yes. Most included studies are comparative. | Generic | Systematic review | 1986-December 2005 | n=43 (n=36 on screening, n=5 follow up testing, n=2 treatment, n=1 survivorship) RCT n=33 CCT=10 | Patient: reminder letters, telephone calls, written educational materials, in-person counseling, mammography vouchers, classroom education Provider: chart reminders, chart flow sheets, written education materials, chart autids with feedback
Mau, 2009 29 | CVD | Native Hawaiians and other Pacific Islanders (NHOPI) | 2 community based samples, 1 clinic sample | Yes | No | Tailored | Systematic review | 1998 - 2008 | 2 pre-post, 1 nonrandomized controlled clinical trial | One study used community health workers to deliver a disease management program. Another study used group visits for hypertension counseling.
Morrow, 2010^20^ | Preventive | Multiethnic groups in the US, including at least 1 disadvantaged group | Community-based | No | Yes | Generic | Systematic review | 1/2001 - 8/2009 | N=15 All RCT | 1. Patient mailings (mailing, tailored mailing, tailored mailing & phone reminder, brochure); N=3; 2. Telephone outreach (scripted and unscripted phone assistance with mailings, care manager calls, tailored phone education); N=3; 3. Electronic and multimedia (physician email system, preferences-based website, standardized website, multimedia computer program education, peer education/health professional video education); N=4; 4. Community education (pts receiving navigator services, community screening behavior program, risk counseling, general counseling, cultural self-empowerment) N=5
Ngo-Metzger, 2010^53^ | Cross-cutting | Asian American patients, though NO articles were found on this population. | All medical settings | Yes | No | Generic | Systematic review | 1/1994-7/2009 | None. Extrapolate from white patients. | Some recommendations at end, none based on any evidence.
Norris, 2006^10^ | Diabetes | SR that includes 8 RCTs; each RCT a single-race group. Minority populations were the target of all studies but 2; majority of participants female and middle-aged. | Unrestricted settings: community health workers could have delivered the intervention in the clinic, home or community setting, in either developed or undeveloped countries. | Yes | No | Generic | Systematic review | 1966 to March 2004 | 18 total: 8 RCTs, 6 before-after studies, 3 non-randomized allocation of treatment and comparison groups, 1 study with postintervention measures only | Community health workers serving in a variety of roles
O'Malley, 2003^17^ | Preventive | Latino and white patients | Primary care settings (community health clinic or doctor's offices) | Yes. A few included studies are single-race. | Yes. Some included studies are comparative, but do not analyze pre-post by race. | Generic | Systematic review | January 1985-January 2003 | n=14 RCT n=5 non-randomized controlled trial n=3 pre-post n=3 quasi-experimental n=3 | Clinical reminders; peer health educators; culturally sensitive videos; audit with feedback; vouchers
Osei-Assibey, 2010^24^ | Preventive | Adults (18 and older). African Americans, Hispanics, Japanese-Americans and white Americans | All 19 included trials conducted in the US, though not specified if in community or health care settings. | Yes. Most included studies are single-race. | Yes. Some included studies are comparative. | Generic | Systematic review | not specified | N=19 all RCT | Culturally tailored advice/diet counseling; individual programs; family/group programs; peer discussion groups; web-based program;
Peek, 2007^8^ | Diabetes | 42 studies in which minority patients were >50% racial makeup, or subgroups of larger trials that were specifically described. | Patient education settings included academic primary care clinics and community based health centers. Provider intervention settings included public hospital academic general internal medicine clinics and community based private physician practices. Health care organization interventions occurred in rural and urban locations, academic and community based primary care clinics, and a public hospital diabetes clinic. | Yes. Most included studies are single-race. | Yes. Some included studies are comparative, but the majority do not analyze pre-post by race. | Generic | Systematic review | 1985-2006 | 22 RCTs, 7 RCTs, 13 before/after studies, 1 observational study. | Systematic review of patient-target interventions that sought to improve dietary habits, physical activity, or self-management activities; physician provider-target interventions; health care organization interventions; and multi-target interventions. Included culturally tailored programs. Many health care organization interventions used a registered nurse for case management and/or clinical management via treatment algorithms, often with a CHF for peer support and community outreach. 2 studies evaluated pharmacist-led medication management and patient education. Multi-target interventions involved more than one of the above targets, e.g. multidisciplinary teams.
Perez-Escamilla, 2008^26^ | Preventive | Latinos in the US | Community and health care settings | Yes. | No. | Tailored | Systematic review | Not specified | n=22 RCTn Pre-post n=13 Cost-benefit n=1 RCTs: 2 in diabetes peer counseling; 2 breastfeeding; 1 food nutrition education Pre-post: 7 in diabetes peer counseling; 2 in breastfeeding; 5 in food nutrition education | Peer educators; nutrition education; nurse case management
Powe, 2010^19^ | Preventive | Individuals aged 50+ and had a study sample of at least 50% African Americans | primary care settings and community based settings | Yes. A few included studies are single-race. | Yes. Most included studies are comparative, but do not analyze pre-post by race. | Generic | Systematic review | 2000-2008 | n=12 RCT n=8 Nonrandom n=4 | Mailed personalized materials; reminder letters/calls; physician reminders; case manager calls; lay health advisors; tailored phone education; physician education
Sarkisian, 2003^11^ | Diabetes | Studies were in single-race groups only. 2 studies were aimed at older adults and did not specify race. | Various: 1 urban hospital, 2 VA's, 1 rural NOS, 1 in Sweden, 1 in Cuba, others named by city NOS. | Yes | No | Generic | systematic review | Jan 1985 - Dec 2000 | 8 RCTs 3 Uncontrolled trials using a before/after design 1 RCT but results were presented using before/after analysis | Self-care interventions that aimed to change the behavior of patients, rather than simply educating them. 4 studies were designed according to cultural criteria specific to the targeted group. Techniques for cultural tailoring included focus groups, and using specific recipes for the ethnic group being studied.
Saxena, 2007^9^ | Diabetes | US populations in 4 studies. Two studies included both African Americans and Hispanics, and 1 study included only African Americans. 1 study appears to have included only Hispanic African Americans. | Primary Care | No | Yes. Some included studies are comparative, but do not analyze pre-post by race. | Generic | systematic review | Database inception to December 2006 | 9 studies (4 in UK, 4 in US, 1 in Netherlands). The 4 US studies included 2 RCTs and 2 CCTs. | Primary care interventions, including case management, patient counseling, and reminder cards to prompt providers
Van Voorhees, 2007^34^ | Mental health | Ethnic minorities and whites; all ages. | Mostly primary care clinics. | No | Yes. Some included studies are comparative, but do not analyze pre-post by race. | Tailored | systematic review | 1/1995 through 1/2006 | 20 interventions total. 12 chronic disease management (9 multicomponent (8 RCTs, 1 observational/cohort) + 3 single component (1 RCT + 2 observational/cohort); 7 case management + 4 collaborative care) + 8 tailored (3 treatment programs + 4 preventive interventions + 1 psychoeducation). | Case management by trained layperson, nurse, or social worker. Some ethnic matching.
Ward, 2007 35 | Mental health | Ethnic minority and white women (n = 5027 with 2136 ethnic minorities) | PCPs, MH clinics, WIC and other targeted service clinics | No | Yes | Generic | Systematic review | 1981 through 2005 | 10 studies (7 RCTs, 1 observational retrospective design, 1 case series, 1 unclear). | QI, case management, guideline-based interventions, collaborative care, standard psychotherapies, cultural adaptations to psychotherapies.
Webb, 2008^21^ | Preventive | African American and whites | Clinical and community | No | Yes | Generic | Meta-analysis | 1984-April 2006 | n=20 Studies coded as quasi-experimental or RCT, but not reported | Pharmacological (sustained-release bupropion, nicotine patches, nicotine lozenge); individual, phone and group behavioral counseling; targeted print materials; community outreach; video/radio media; multicomponent of above
Webb, 2010^22^ | Preventive | healthy US Hispanic adults | Home visits, health care settings, community settings | Yes | No | Generic | Systematic review and mini meta-analysis | 1991-2007 | n=17 n=12 for SR RCT n=5 for MA | Self help; nicotine replacement therapy; community based interventions; individual counseling; group counseling; telephone counseling
Whitt-Glover, 2009^23^ | Preventive | African Americans | Community (churches, YMCA, community centers, public housing) and health care settings (doctor offices, hospitals) | No | Yes | Generic | Systematic review | September 2002-December 2006 | n=29 (additional n=14 on children are not considered here)-RC=-NCT=4 (non-randomized controlled trials-UCT=10 (uncontrolled trial) | Telephone counseling; peer counselors; structured exercise program; group exercise sessions; unstructured/unsupervised exercise

Abbreviations: CHW – community health worker, CVD – cardiovascular disease, DM – diabetes mellitus, ESP – Evidence-based Synthesis Program, GP – general practitioner, HE – health education, HSR&D – Health Services Research and Development Service, MH – mental health, NOS – not otherwise specified, PCP – primary care provider, RCT – randomized controlled trial, VAMC – VA Medical Center, WIC - Special Supplemental Nutrition Program for Women, Infants and Children