# QUALITY RATING CRITERIA FOR REVIEWS

Overall quality rating for systematic reviews is based on the questions below. Ratings are summarized as: Good, Fair, or Poor:^*^

* Created from the following publications:

Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229]. National Institute for Health and Clinical Excellence, The Guidelines Manual. London. Institute for Health and Clinical Excellence. 2006. Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-8. [pmid: 1834807].

- Search dates reported? Yes or No
- Search methods reported? Yes or No
- Comprehensive search? Yes or No
- Inclusion criteria reported? Yes or No
- Selection bias avoided? Yes or No
- Validity criteria reported? Yes or No
- Validity assessed appropriately? Yes or No
- Methods used to combine studies reported? Yes or No
- Findings combined appropriately? Yes or No
- Conclusions supported by data? Yes or No

## Definitions of ratings based on above criteria

[underlined: Good]: Meet all criteria: Reports comprehensive and reproducible search methods and results; reports pre-defined criteria to select studies and reports reasons for excluding potentially relevant studies; adequately evaluates quality of included studies and incorporates assessments of quality when synthesizing data; reports methods for synthesizing data and uses appropriate methods to combine data qualitatively or quantitatively; conclusions supported by the evidence reviewed.

[underlined: Fair]: Studies will be graded fair if they fail to meet one or more of the above criteria, but the limitations are not judged as being major.

[underlined: Poor]: Studies will be graded poor if they have a major limitation in one or more of the above criteria.