# INCLUSION/EXCLUSION CRITERIA FOR PRIMARY STUDIES AND REVIEWS

1. Is the full text of the article in English?
  Yes | Proceed to #2
  No | Code X1. Go to #6
2. Does the study population include adults in the U.S.?
  Yes | Proceed to #3
  No | Code X2. Go to #6
3. Does the article evaluate the effects of an intervention within one or more racial/ethnic minority group(s), or between racial/ethnic groups including at least one racial/ethnic minority group?
  Yes | Proceed to #4
  No | Code X3. Go to #6
4. Is the publication a primary study conducted in a VA population, or a systematic review or meta-analysis (not limited to VA) that meets methodological quality criteria?
  Yes | Proceed to #5
  No | Code X4. Proceed to #6
5. Is the intervention applicable to VA care settings?
  (Applicability refers to patient populations and disease entities of documented disparities in the VA setting. Qualifying interventions must target services provided at the VA. Obstetric care and interventions designed to improve access are examples of exclusions)
  Yes | Code I5. STOP
  No | Code X5. Proceed to #6
6. Is the article potentially useful for background, discussion, or reference-mining?
  Yes | Add code B. STOP
  No | STOP

## PICOTS

Population: adults in the US. Studies exclusively on children or adolescents are excluded.

Interventions: third generation studies that evaluate the effects of an intervention within one or more racial/ethnic minority group(s) or between racial/ethnic groups including at least one racial/ethnic minority group.

Comparator: control group within same racial/ethnic minority group, or comparison between racial/ethnic groups.

Outcomes: not limited. outcomes of interest include the following:

i. Utilization of health care services
ii. Quality of health care services
  1. Process of care measures (e.g., use of appropriate screening tests)
  2. Outcome measures used by VHA as quality metrics (e.g., blood pressure control)
  3. Patient evaluations of care (e.g., patient satisfaction)
  4. Direct observations of care (e.g., communication patterns)
iii. Potential mediators of racial/ethnic disparities in utilization or quality
  1. System-level mediators (e.g., distribution of services)
  2. Provider-level mediators (e.g., racial bias)
  3. Patient-level mediators (e.g., trust)
iv. Patient-provider level mediators (e.g., communication)
v. Health outcomes (e.g., diabetic complications)

Timing: any length of followup

Setting: US