# SEARCH STRATEGY

## I SEARCH FOR INTERVENTION STUDIES TO REDUCE RACIAL DISPARITIES

Search | Most Recent Queries | Time | Result
[underlined: #12] | Search systematic[sb] AND (#9) | 15:47:12 | 2129
[underlined: #9] | Search (#8) OR #6 | 15:43:46 | 83980
[underlined: #8] | Search (#4) AND #7 | 15:43:29 | 25879
[underlined: #7] | Search “Evaluation Studies “[Publication Type] OR “Clinical Trial “[Publication Type] | 15:43:08 | 751037
[underlined: #6] | Search (#5) AND #4 | 15:42:49 | 65155
[underlined: #5] | Search address OR program OR intervention* OR reduce OR eliminate[Title/Abstract] | 15:42:38 | 1106596
[underlined: #4] | Search ((#3) OR #2) OR #1 | 15:42:29 | 491858
[underlined: #3] | Search ((“Population Groups”[Mesh] OR “Race Relations”[Mesh]) OR “Minority Groups”[Mesh]) OR “Health Services Accessibility”[Mesh] | 15:41:47 | 229846
[underlined: #2] | Search ethnic* OR race or Racial OR disparity OR disparities OR blacks OR black OR hispanic* OR equity OR sociodemographic OR discrimination OR minority OR minorities OR “African american*”[Title/Abstract] | 15:41:36 | 425423
[underlined: #1] | Search (((“African Continental Ancestry Group”[Mesh] OR “Hispanic Americans”[Mesh]) OR “Indians, North American”[Mesh]) OR “Inuits”[Mesh]) OR “Asian Americans”[Mesh] | 15:41:16 | 77830

## II UPDATE SEARCH FOR RECENTLY PUBLISHED STUDIES USING THE STRATEGY DESIGNED FOR THE 2007 VA- ESP REVIEW OF PRIMARY VA STUDIES

### Search terms in PubMed Database Searched August 12, 2010

((VA [tw] OR veteran* [tw]) OR (United States Department of Veterans Affairs [mh] OR veterans [mh] OR veterans hospitals [mh])) AND ((ethnic* [tw] OR race [tw] OR racial [tw] OR disparity [tw] OR disparities [tw] OR blacks [tw] OR black [tw] OR Hispanic* [tw]) OR (population groups [mh] OR race relations [mh])) AND ((“2006/10/01”[PDat] : “3000”[PDat]))

Result: 533

### Search terms in HSRProj Database Searched August 12, 2010

VA and (disparity OR disparities OR equity)

and Project Status = Ongoing & Completed (Default)

and Initial Year from: 2006 To: 2010

States: All

Result: 31 Projects

## III Search for systematic reviews of intervention studies on racial disparities

Search | Most Recent Queries
#12 | Search systematic[sb] AND (#9)
#9 | Search (#8) OR #6
#8 | Search (#4) AND #7
#7 | Search “Evaluation Studies “[Publication Type] OR “Clinical Trial “[Publication Type]
#6 | Search (#5) AND #4
#5 | Search address OR program OR intervention* OR reduce OR eliminate[Title/Abstract]
#4 | Search ((#3) OR #2) OR #1
#3 | Search ((“Population Groups”[Mesh] OR “Race Relations”[Mesh]) OR “Minority Groups”[Mesh]) OR “Health Services Accessibility”[Mesh]
#2 | Search ethnic* OR race or Racial OR disparity OR disparities OR blacks OR black OR hispanic* OR equity OR sociodemographic OR discrimination OR minority OR minorities OR “African american*”[Title/Abstract]
#1 | Search (((“African Continental Ancestry Group”[Mesh] OR “Hispanic Americans”[Mesh]) OR “Indians, North American”[Mesh]) OR “Inuits”[Mesh]) OR “Asian Americans”[Mesh]