# SUMMARY AND SYNTHESIS

## Prevalence of disparities

In the tables below, we categorize the findings of reviewed studies by clinical content area (Table 9) and by utilization or outcome measure (Table 10).

Table 9 Presence of Disparities by Clinical Content Area

Clinical Content Area | Disparities Present | Disparities Not Present
Arthritis/pain management | 6 | 1
Cancer treatment | 2 | 2
Diabetes | 7 | 2
Heart and vascular disease | 20 | 10
HIV/Hepatitis C | 4 | 3
Mental health/substance abuse | 11 | 10
Preventive/ambulatory care | 8 | 4
Rehabilitation and palliative care | 2 | 2

Table 10 Presence of Disparities by Utilization or Outcome Measure

Utilization or Outcome Measure | Disparities Present | Disparities Not Present
Surgery and invasive procedures | 21 | 11
Medication use
Prescribing | 9 | 7
Adherence | 5 | 0
Basic services/processes of care^*^ | 13 | 10
Referral | 1 | 2
Patient satisfaction | 2 | 3
Intermediate outcomes^**^ | 5 | 1

* E.g., lab tests, outpatient visits

** E.g., control of blood pressure, blood glucose, lipids

In Table 9, we categorized each unique study in our review as finding disparities to be present vs. not present. When a single study examined multiple utilization or outcome measures, the findings for each measure were entered into Table 10 (e.g., if a study found racial differences in the use of a surgical procedure but no racial differences in the use of a prescription medication, it would have contributed one point to the “Disparities Present” column under “Surgery and Invasive Procedures,” and one point to the “Disparities Not Present” column under “Medication Use/Prescribing.” In addition, when studies found more or higher-quality care for non-white veterans compared to whites, that study was counted in the “Disparities Not Present” column, to maintain consistency with the vast majority of the literature demonstrating less or lower quality care for non-whites. The one exception to this rule involved cases in which non-whites received more services that generally indicate lower quality care or worse outcomes (e.g., limb amputation).

These tables are intended to provide a rough “landscape” of the existing literature. They should not be construed as an accurate quantification of the distribution of disparities within the VA, since they do not account for the quality, sample size, or generalizability of the individual studies, or for the degree of disparities found (i.e., effect size). In addition, studies under the “Disparities Not Present” column did not necessarily establish the absence of disparities, but rather did not find disparities to be present; these studies often did not have adequate power to definitively demonstrate equivalence between racial groups.

There are several points worth noting with regard to the presence of disparities within the VA.

- There is no clear indication that disparities are more prevalent in some clinical content areas than others. Although there have been more studies in the area of cardiovascular disease than in other realms (as is also true in the non-VA literature), disparities appear to exist in all clinical arenas.
- Disparities appear to be more consistently observed for processes that entail more risk or require more intensive decision making, communication, or effort on the part of patients and/or providers: surgery/invasive procedures and medication adherence.
- In studies examining quality indicators that represent intermediate health outcomes—such as control of blood sugar, blood pressure, or cholesterol—non-white veterans generally fared worse than whites. This is a troubling finding, in that it may indicate that disparities in healthcare delivery are contributing to real disparities in health outcomes. Alternatively, these studies suggest that racial disparities might reflect “regressive” healthcare delivery; i.e., minority veterans are receiving less and lower quality health care despite needing more and higher quality care, as reflected by poor control of their diabetes, hypertension, and hyperlipidemia.
- Most of the reviewed studies compared African American and white veterans. Fewer studies examined Hispanics, American Indians, and Asians. In general, disparities in the VA appear to affect African American and Hispanic veterans most significantly.
- Not all disparities should be assumed to reflect underuse of health care among non-whites, particularly in the realm of surgical and other invasive procedures. In at least one study, differential use of cardiovascular procedures was found to reflect overuse among whites rather than underuse among African Americans.31 However, in many cases, disparities do appear to represent inappropriate underuse of procedures (i.e., lower quality care) among non-whites.
- Because white veterans tend to use non-VA care more often than non-white veterans do, studies that do not capture non-VA utilization, particularly those using administrative data, may underestimate the degree of disparities, find disparities to be absent when they in fact exist,60 or find “reverse” disparities (non-whites receive more/better care) when in fact no disparities exist.138 At least two studies have demonstrated this misleading effect of not capturing non-VA utilization.60, 138

## Sources of disparities

Firm conclusions about the sources of disparities within the VA are limited by several issues. First, relative to the number of studies examining the presence or absence of disparities, there are far fewer studies examining potential causes of disparities. Second, the VA disparities literature is complex. Studies are highly varied in terms of study settings and populations, clinical topics and services, data collection methods, and measures. This variability makes it difficult to generate unifying theories that are generalizable across settings and services. Finally, most studies examining potential sources of disparities focus on whether a hypothesized cause (e.g., communication patterns) varies by veteran race or ethnicity, but not on the degree to which that cause helps explains the disparity that motivated the study (e.g., differential use of cancer surgery by race). For example, one study found that African American veterans with lung cancer are less likely to undergo surgical tumor resection than white veterans.21 In a subsequent study, investigators hypothesized that this disparity might be explained by different patterns of patient-physician communication and veteran trust in physicians, by race.23, 24 They found that communication patterns and trust did indeed differ by race. However, because of the relatively small number of patients in their study, they were not able to examine whether differential communication patterns and trust helped explain differences in lung cancer surgery. This is a pervasive limitation, because the detailed data needed for studies exploring potential causes of disparities—which often involve surveys, chart review, or qualitative research methods—are often difficult to collect in numbers large enough to determine whether those potential causes explain observed disparities, which are often documented using large administrative data sets.

Acknowledging the limitations described above, several themes emerged from our review as likely contributors to racial disparities in VA health care. These themes are rooted in our systematic review of the evidence but are based on qualitative rather than quantitative synthesis (e.g., meta-analysis). Our synthesis of research findings should therefore be considered a guide for future research, as opposed to firm, statistically derived conclusions.

- Veteran medical knowledge and information sources. Non-white and white veterans differ in their degree of familiarity with and knowledge about medical interventions. This difference stems from different levels of experience with those interventions among minority vs. white veterans and their families, friends, and communities; from different amounts of information conveyed by healthcare providers; and from different levels of health literacy and understanding among veterans. Different knowledge and information may affect patients’ perceptions of, or degree of uncertainty about, the necessity and benefits of medical interventions in relation to their risks. Uncertainty about the necessity of interventions may in turn reduce patients’ willingness to accept and adhere to them. Several studies indicate that minority veterans are less informed about their care, as compared to white veterans, and that this difference affects decision making.23, 24, 53, 113, 114, 122, 137
- Veteran trust and skepticism. Minority veterans also tend to harbor less trust and more skepticism about the benefits of medical interventions, relative to their risks. These perceptions appear to be influenced by lack of familiarity with medical interventions (described above), by historical or personally experienced discrimination, and for some African American veterans in particular, by a reliance on religious and spiritual avenues for coping with illness as opposed to medical therapies. Studies in our review suggest that minority veterans are more skeptical of information provided by healthcare professionals, as compared to white veterans.23, 45, 51, 52, 54 It is important, however, not to misconstrue this skepticism as unwarranted. White veterans’ general lack of skepticism may be more problematic if it leads to acceptance of unnecessary or undesired care.
- Racial/cultural milieu. Some have suggested that a more racially and culturally congruent healthcare environment (including racially concordant healthcare providers) for minority veterans may elevate trust, reduce skepticism, and enhance the acceptability of care. Two studies directly examined this issue and found that African American veterans experienced better interactions and fared somewhat better clinically, when cared for by African American vs. white providers.53, 102 Another study suggested that black patients in group therapy might fare better when grouped with other black patients.76
- Patient participation. Several studies suggest that non-white veterans are less active participants in their care as compared to white veterans.24, 26, 53, 102,113 Non-white veterans tend to ask fewer questions of their providers, who in turn provide less information. Less information, as discussed above, may lead to lower acceptance of and adherence to medical interventions. In addition, lower patient participation diminishes the strength of the patient-provider partnership, which may in turn lead to less investment by both parties in following recommended care plans, and to lower trust and greater skepticism among minority veterans.
- Clinician judgment. Studies suggest that clinicians’ diagnostic and therapeutic decision making varies by veteran race. The degree to which this differential decision making is based on clinical factors vs. non-clinical factors, including racial stereotypes, is unclear. For instance, in one study clinicians judged African American veterans to be less appropriate candidates for coronary interventions, even after accounting for chart-documented variables.45 The degree to which this judgment reflected undocumented clinical factors vs. non-clinical influences was not clear. Similarly, clinicians prescribe opioid medications less frequently to African American vs. white veterans2 and are more likely to diagnose African American veterans presenting with mental illness as having psychotic vs. affective disorders.79, 80 The degree to which these phenomena are driven by racial differences in co-existing substance abuse disorders, by cross-cultural misunderstanding of symptom presentations, or by racial bias, remains unclear.
- Veteran social support and resources. Non-white veterans may have fewer social support and other external resources to help with both illness management and decision making. This is particularly relevant in that minority veterans may rely more heavily on external resources than on healthcare professionals for information and support. This may particularly affect adherence and decision making around high-risk procedures.68
- Healthcare facility characteristics. Some disparities are at least partly explained by the fact that minority and white veterans tend to receive care at different VA Medical Centers.61 (Heisler M, unpublished; Groeneveld PW, unpublished) In some cases, VA Medical Centers that disproportionately serve minority veterans have fewer available services or deliver lower quality care overall than VAMCs serving predominantly white veterans. This potential source of disparities, however, remains underexplored. It should be noted that many studies have demonstrated disparities within single VAMCs, suggesting that system-level factors are unlikely to explain all observed disparities.

## Future Research Recommendations

The findings of our review suggest several promising areas for future research to further elucidate and reduce/eliminate racial disparities in health care within the VA.

- Decision aids and information tools. Because disparities may arise from different levels of familiarity with and information about medical interventions, tools that provide accurate information about the rationale, risks, and benefits of interventions have the potential to “even the playing field” among minority and white veterans in terms of knowledge. Such tools, many of which use computer technology to help patients better understand not only medical interventions but also their own preferences, also have the potential to make patients more active participants in their medical care, which may improve understanding and adherence. In designing decision aids and information tools for minority veterans, investigators should pay attention to issues of literacy, language, and culture.
- Patient activation interventions. Interventions to make patients more active participants in their interactions with healthcare providers and in the management of their illnesses have been shown to improve health outcomes. They may also reduce disparities by breaking the cycle of passivity that leads to less information exchange between minority veterans and their healthcare providers. More active patient participation has the potential to improve patient adherence as well as to strengthen patient-provider partnerships and mutual trust.
- Patient-centered communication training. Interventions to make veterans more active participants in their interactions with healthcare providers can also target providers. Clinicians can adopt communication strategies that help solicit patient perspectives and engage patient participation. As with patient activation interventions, patient-centered approaches to healthcare interactions hold the potential to strengthen patient-provider partnerships and mutual trust.
- Determining sources of variation in clinician judgment by patient race. As described above, studies have found that clinicians make different judgments based on veteran race. However, the degree to which this variation is driven by clinical characteristics vs. non-clinical factors, such as racial bias, remains unclear. Studies exploring how and why patient race is associated with different clinical decisions would help determine the need for and inform interventions to reduce adverse consequences of racial bias among clinicians.
- Interventions to promote evidence-based decision making by providers. Similar to decision aids and information tools for patients, guidelines and decision rules for providers hold the potential to improve equity by “standardizing” care. To the extent that providers may be biased by patient race, guidelines, decision rules, and other quality improvement tools that promote evidence-based decision making may reduce the influence of provider bias and enhance equity of care among veterans of different race and ethnicity.
- Adherence support interventions. Minority veterans appear consistently across studies to be less adherent to treatment plans than whites. Studies suggest that this may in part be due to less social support and planning among minority veterans. Interventions to provide adherence support—e.g., education, assistance with care planning—may help reduce this disparity.
- Determining facility characteristics associated with healthcare quality and equity. Some disparities are explained by differences in the healthcare facilities where minority vs. white veterans seek care. Determining the differences in structures and processes across minority- vs. majority-serving VAMCs would inform interventions to eliminate system-level sources of disparities. In addition, studies examining facility-level characteristics associated with more equitable care within VAMCs—including those related to the racial and cultural context at VAMCs, such as the racial composition of clinical staff—would help inform system-level interventions to eliminate disparities.

Future research on disparities in VA healthcare should explicitly define how race is conceptualized within a given study. A group of VA investigators has developed a survey/interview tool to assess the “ecocultural” factors for which veterans’ race and ethnicity often serve as proxies.66 “Unpacking” race and ethnicity in studies of disparities will promote understanding and inform future interventions. Researchers should also be mindful that some disparities represent overuse of medical services among white veterans rather than underuse among non-whites. Clearly, interventions to promote greater use of services among non-whites in these instances is unwarranted. Finally, future studies should attempt to account for non-VA utilization. Because non-VA care is more prevalent among white veterans than among non-whites, ignoring non-VA utilization may generate misleading results.