# REFERENCES

1 Smedley BD, Stith AY, Nelson AR, Institute of Medicine Committee on Understanding and Eliminating Racial and Ethnic Disparities in Health Care. Unequal treatment: confronting racial and ethnic disparities in health care. Washington, D.C. National Academies Press. 2003.
2 Dominick KL, Bosworth HB, Dudley TK, Waters SJ, Campbell LC, Keefe FJ. Patterns of opioid analgesic prescription among patients with osteoarthritis. J Pain Palliat Care Pharmacother. 2004;18(1):31-46. [pmid: 15148007].
3 Dominick KL, Bosworth HB, Hsieh JB, Moser BK. Racial differences in analgesic/anti-inflammatory medication use and perceptions of efficacy. J Natl Med Assoc. Jul. 2004;96(7):928-932. [pmid: 15253323].
4 Dominick KL, Bosworth HB, Jeffreys AS, Grambow SC, Oddone EZ, Horner RD. Racial/ethnic variations in non-steroidal anti-inflammatory drug (NSAID) use among patients with osteoarthritis. Pharmacoepidemiol Drug Saf. Oct. 2004;13(10):683-694. [pmid: 15386734].
5 Dominick KL, Golightly YM, Bosworth HB. Racial differences in analgesic/anti-inflammatory medication adherence among patients with osteoarthritis. Ethn Dis. Winter. 2005;15(1):116-122. [pmid: 15720058].
6 Dominick KL, Dudley TK, Grambow SC, Oddone EZ, Bosworth HB. Racial differences in health care utilization among patients with osteoarthritis. J Rheumatol. Oct. 2003;30(10):2201-2206. [pmid: 14528518].
7 Selim AJ, Fincke G, Ren XS, et al. Racial differences in the use of lumbar spine radiographs: results from the Veterans Health Study. Spine. Jun 15. 2001;26(12):1364-1369. [pmid: 11426153].
8 Jones A, Kwoh CK, Kelley ME, Ibrahim SA. Racial disparity in knee arthroplasty utilization in the veterans health administration. Arthritis Rheum. Dec 15. 2005;53(6):979-981. [pmid: 16342110].
9 Golightly YM, Dominick KL. Racial variations in self-reported osteoarthritis symptom severity among veterans. Aging Clin Exp Res. Aug. 2005;17(4):264-269. [pmid: 16285190].
10 Ang DC, Ibrahim SA, Burant CJ, Kwoh CK. Is there a difference in the perception of symptoms between african americans and whites with osteoarthritis?. J Rheumatol. Jun. 2003;30(6):1305-1310. [pmid: 12784407].
11 Ibrahim SA, Burant CJ, Mercer MB, Siminoff LA, Kwoh CK. Older patients’ perceptions of quality of chronic knee or hip pain: differences by ethnicity and relationship to clinical variables. J Gerontol A Biol Sci Med Sci. May. 2003;58(5):M472-477. [pmid: 12730259].
12 Tan G, Jensen MP, Thornby J, Anderson KO. Ethnicity, control appraisal, coping, and adjustment to chronic pain among black and white Americans. Pain Med. Jan–Feb. 2005;6(1):18-28. [pmid: 15669947].
13 Allen KD, Golightly YM, Olsen MK. Pilot study of pain and coping among patients with osteoarthritis: a daily diary analysis. J Clin Rheumatol. Jun. 2006;12(3):118-123. [pmid: 16755238].
14 Ang DC, Ibrahim SA, Burant CJ, Siminoff LA, Kwoh CK. Ethnic differences in the perception of prayer and consideration of joint arthroplasty. Med Care. Jun. 2002;40(6):471-476. [pmid: 12021673].
15 Ibrahim SA, Siminoff LA, Burant CJ, Kwoh CK. Differences in expectations of outcome mediate African American/white patient differences in “willingness” to consider joint replacement. Arthritis Rheum. Sep. 2002;46(9):2429-2435. [pmid: 12355491].
16 Ibrahim SA, Siminoff LA, Burant CJ, Kwoh CK. Understanding ethnic differences in the utilization of joint replacement for osteoarthritis: the role of patient-level factors. Med Care. Jan. 2002;40(1 Suppl):I44-51. [pmid: 11789631].
17 Lopez JP, Burant CJ, Siminoff LA, Kwoh CK, Ibrahim SA. Patient perceptions of access to care and referrals to specialists: a comparison of African-American and white older patients with knee and hip osteoarthritis. J Natl Med Assoc. May. 2005;97(5):667-673. [pmid: 15926643].
18 Ibrahim SA, Siminoff LA, Burant CJ, Kwoh CK. Variation in perceptions of treatment and self-care practices in elderly with osteoarthritis: a comparison between African American and white patients. Arthritis & Rheumatism. Aug. 2001;45(4):340-345. [pmid: 11501721].
19 Dominitz JA, Samsa GP, Landsman P, Provenzale D. Race, treatment, and survival among colorectal carcinoma patients in an equal-access medical system. Cancer. Jun 15. 1998;82(12):2312-2320. [pmid: 9635522].
20 Dominitz JA, Maynard C, Billingsley KG, Boyko EJ. Race, treatment, and survival of veterans with cancer of the distal esophagus and gastric cardia. Med Care. Jan. 2002;40(1 Suppl):I14-26. [pmid: 11789626].
21 Akerley WL 3rd, Moritz TE, Ryan LS, Henderson WG, Zacharski LR. Racial comparison of outcomes of male Department of Veterans Affairs patients with lung and colon cancer. Arch Intern Med. Jul 26. 1993;153(14):1681-1688. [pmid: 8333805].
22 Knight SJ, Siston AK, Chmiel JS, et al. Ethnic variation in localized prostate cancer: a pilot study of preferences, optimism, and quality of life among black and white veterans. Clin Prostate Cancer. Jun. 2004;3(1):31-37. [pmid: 15279688].
23 Gordon HS, Street RL Jr, Sharf BF, Kelly PA, Souchek J. Racial differences in trust and lung cancer patients’ perceptions of physician communication. J Clin Oncol. Feb 20. 2006;24(6):904-909. [pmid: 16484700].
24 Gordon HS, Street RL Jr, Sharf BF, Souchek J. Racial differences in doctors’ information-giving and patients’ participation. Cancer. Sep 15. 2006;107(6):1313-1320. [pmid: 16909424].
25 Margolis ML, Christie JD, Silvestri GA, Kaiser L, Santiago S, Hansen-Flaschen J. Racial differences pertaining to a belief about lung cancer surgery: results of a multicenter survey. Ann Intern Med. Oct 7. 2003;139(7):558-563. [pmid: 14530226].
26 Street RL Jr, Gordon HS. The clinical context and patient participation in post-diagnostic consultations. Patient Educ Couns. Jul. 19. 2006. in press.
27 Oddone EZ, Horner RD, Monger ME, Matchar DB. Racial variations in the rates of carotid angiography and endarterectomy in patients with stroke and transient ischemic attack. Arch Intern Med. Dec 27. 1993;153(24):2781-2786. [pmid: 8257254].
28 Oddone EZ, Horner RD, Sloane R, et al. Race, presenting signs and symptoms, use of carotid artery imaging, and appropriateness of carotid endarterectomy. Stroke. Jul. 1999;30(7):1350-1356. [pmid: 10390306].
29 Goldstein LB, Matchar DB, Hoff-Lindquist J, Samsa GP, Horner RD. Veterans Administration Acute Stroke (VASt) Study: lack of race/ethnic-based differences in utilization of stroke-related procedures or services. Stroke. Apr. 2003;34(4):999-1004. [pmid: 12649513].
30 Oddone EZ, Horner RD, Johnston DC, et al. Carotid endarterectomy and race: do clinical indications and patient preferences account for differences?. Stroke. Dec. 2002;33(12):2936-2943. [pmid: 12468794].
31 Ferguson JA, Adams TA, Weinberger M. Racial differences in cardiac catheterization use and appropriateness. Am J Med Sci. May. 1998;315(5):302-306. [pmid: 9587086].
32 Hassapoyannes CA, Giurgiutiu DV, Eaves G, Movahed MR. Apparent racial disparity in the utilization of invasive testing for risk assessment of cardiac patients undergoing noncardiac surgery. Cardiovasc Revasc Med. Apr–Jun. 2006;7(2):64-69. [pmid: 16757403].
33 Mirvis DM, Burns R, Gaschen L, Cloar FT, Graney M. Variation in utilization of cardiac procedures in the Department of Veterans Affairs health care system: effect of race. J Am Coll Cardiol. Nov 1. 1994;24(5):1297-1304. [pmid: 7930253].
34 Maynard C, Sun H, Lowy E, Sales AE, Fihn SD. The use of percutaneous coronary intervention in black and white veterans with acute myocardial infarction. BMC Health Serv Res. 2006;6:107. [pmid: 16923183].
35 Ferguson JA, Tierney WM, Westmoreland GR, et al. Examination of racial differences in management of cardiovascular disease. J Am Coll Cardiol. Dec. 1997;30(7):1707-1713. [pmid: 9385897].
36 Peterson ED, Wright SM, Daley J, Thibault GE. Racial variation in cardiac procedure use and survival following acute myocardial infarction in the Department of Veterans Affairs. Jama. Apr 20. 1994;271(15):1175-1180. [pmid: 8151875].
37 Whittle J, Conigliaro J, Good CB, Lofgren RP. Racial differences in the use of invasive cardiovascular procedures in the Department of Veterans Affairs medical system. N Engl J Med. Aug 26. 1993;329(9):621-627. [pmid: 8341338].
38 Peniston RL, Lu DY, Papademetriou V, Fletcher RD. Severity of coronary artery disease in black and white male veterans and likelihood of revascularization. Am Heart J. May. 2000;139(5):840-847. [pmid: 10783218].
39 Conigliaro J, Whittle J, Good CB, et al. Understanding racial variation in the use of coronary revascularization procedures: the role of clinical factors. Arch Intern Med. May 8. 2000;160(9):1329-1335. [pmid: 10809037].
40 Petersen LA, Wright SM, Peterson ED, Daley J. Impact of race on cardiac care and outcomes in veterans with acute myocardial infarction. Medical Care. Jan. 2002;40(1 Suppl):I86-96. [pmid: 11789635].
41 Sedlis SP, Fisher VJ, Tice D, Esposito R, Madmon L, Steinberg EH. Racial differences in performance of invasive cardiac procedures in a Department of Veterans Affairs Medical Center. J Clin Epidemiol. Aug. 1997;50(8):899-901. [pmid: 9291874].
42 Mickelson JK, Blum CM, Geraci JM. Acute myocardial infarction: clinical characteristics, management and outcome in a metropolitan Veterans Affairs Medical Center teaching hospital. J Am Coll Cardiol. Apr. 1997;29(5):915-925. [pmid: 9120176].
43 Mirvis DM, Graney MJ. Impact of race and age on the effects of regionalization of cardiac procedures in the Department of Veterans Affairs Health Care System. Am J Cardiol. Apr 15. 1998;81(8):982-987. [pmid: 9576157].
44 Gordon HS, Paterniti DA, Wray NP. Race and patient refusal of invasive cardiac procedures. J Gen Intern Med. Sep. 2004;19(9):962-966. [pmid: 15333061].
45 Kressin NR, Chang BH, Whittle J, et al. Racial differences in cardiac catheterization as a function of patients’ beliefs. Am J Public Health. Dec. 2004;94(12):2091-2097. [pmid: 15569959].
46 Groeneveld PW, Kruse GB, Chen Z, Asch DA. Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals. American Heart Journal. Feb. 2007;153(2):320-327. [pmid: 17239696].
47 Collins TC, Johnson M, Henderson W, Khuri SF, Daley J. Lower extremity nontraumatic amputation among veterans with peripheral arterial disease: is race an independent factor?. Med Care. Jan. 2002;40(1 Suppl):I106-116. [pmid: 11789623].
48 Charles H, Good CB, Hanusa BH, Chang CC, Whittle J. Racial differences in adherence to cardiac medications. J Natl Med Assoc. Jan. 2003;95(1):17-27. [pmid: 12656446].
49 Deswal A, Petersen NJ, Urbauer DL, Wright SM, Beyth R. Racial variations in quality of care and outcomes in an ambulatory heart failure cohort. American Heart Journal. Aug. 2006;152(2):348-354. [pmid: 16875921].
50 Ohldin A, Young B, Derleth A, et al. Ethnic differences in satisfaction and quality of life in veterans with ischemic heart disease. J Natl Med Assoc. Jun. 2004;96(6):799-808. [pmid: 15233490].
51 Kressin NR, Clark JA, Whittle J, et al. Racial differences in health-related beliefs, attitudes, and experiences of VA cardiac patients: scale development and application. Med Care. Jan. 2002;40(1 Suppl):I72-85. [pmid: 11789634].
52 Collins TC, Clark JA, Petersen LA, Kressin NR. Racial differences in how patients perceive physician communication regarding cardiac testing. Med Care. Jan. 2002;40(1 Suppl):I27-34. [pmid: 11789628].
53 Gordon HS, Street RL Jr, Kelly PA, Souchek J, Wray NP. Physician-patient communication following invasive procedures: an analysis of post-angiogram consultations. Soc Sci Med. Sep. 2005;61(5):1015-1025. [pmid: 15955403].
54 Bosworth HB, Stechuchak KM, Grambow SC, Oddone EZ. Patient risk perceptions for carotid endarterectomy: which patients are strongly averse to surgery?. J Vasc Surg. Jul. 2004;40(1):86-91. [pmid: 15218467].
55 Oddone EZ, Horner RD, Diers T, et al. Understanding racial variation in the use of carotid endarterectomy: the role of aversion to surgery. J Natl Med Assoc. Jan. 1998;90(1):25-33. [pmid: 9473926].
56 Whittle J, Conigliaro J, Good CB, Joswiak M. Do patient preferences contribute to racial differences in cardiovascular procedure use?. J Gen Intern Med. May. 1997;12(5):267-273. [pmid: 9159695].
57 Evangelista LS, Dracup K, Doering LV. Racial differences in treatment-seeking delays among heart failure patients. J Card Fail. Dec. 2002;8(6):381-386. [pmid: 12528090].
58 Ibrahim SA, Whittle J, Bean-Mayberry B, Kelley ME, Good C, Conigliaro J. Racial/ethnic variations in physician recommendations for cardiac revascularization. Am J Public Health. Oct. 2003;93(10):1689-1693. [pmid: 14534223].
59 Lowry KP, Dudley TK, Oddone EZ, Bosworth HB. Intentional and unintentional nonadherence to antihypertensive medication. Ann Pharmacother. Jul–Aug. 2005;39(7–8):1198-1203. [pmid: 15956238].
60 Halanych JH, Wang F, Miller DR, et al. Racial/ethnic differences in diabetes care for older veterans: accounting for dual health system use changes conclusions. Medical Care. May. 2006;44(5):439-445. [pmid: 16641662].
61 Heisler M, Smith DM, Hayward RA, Krein SL, Kerr EA. Racial disparities in diabetes care processes, outcomes, and treatment intensity. Medical Care. Nov. 2003;41(11):1221-1232. [pmid: 14583685].
62 Safford M, Eaton L, Hawley G, et al. Disparities in use of lipid-lowering medications among people with type 2 diabetes mellitus. Arch Intern Med. Apr 28. 2003;163(8):922-928. [pmid: 12719201].
63 Cramer JA, Pugh MJ. The influence of insulin use on glycemic control: How well do adults follow prescriptions for insulin?. Diabetes Care. Jan. 2005;28(1):78-83. [pmid: 15616237].
64 Wendel CS, Shah JH, Duckworth WC, Hoffman RM, Mohler MJ, Murata GH. Racial and ethnic disparities in the control of cardiovascular disease risk factors in Southwest American veterans with type 2 diabetes: the Diabetes Outcomes in Veterans Study. BMC Health Serv Res. 2006;6:58. [pmid: 16716235].
65 Young BA, Maynard C, Reiber G, Boyko EJ. Effects of ethnicity and nephropathy on lower-extremity amputation risk among diabetic veterans. Diabetes Care. Feb. 2003;26(2):495-501. [pmid: 12547888].
66 Walsh ME, Katz MA, Sechrest L. Unpacking cultural factors in adaptation to type 2 diabetes mellitus. Med Care. Jan. 2002;40(1 Suppl):I129-139. [pmid: 11789625].
67 Singh N, Squier C, Sivek C, Wagener M, Nguyen MH, Yu VL. Determinants of compliance with antiretroviral therapy in patients with human immunodeficiency virus: prospective assessment with implications for enhancing compliance. AIDS Care. Jun. 1996;8(3):261-269. [pmid: 8827119].
68 Kemppainen JK, Levine RE, Mistal M, Schmidgall D. HAART adherence in culturally diverse patients with HIV/AIDS: a study of male patients from a Veteran’s Administration Hospital in northern California. AIDS Patient Care STDS. Mar. 2001;15(3):117-127. [pmid: 11313024].
69 McGinnis KA, Fine MJ, Sharma RK, et al. Understanding racial disparities in HIV using data from the veterans aging cohort 3-site study and VA administrative data. Am J Public Health. Oct. 2003;93(10):1728-1733. [pmid: 14534229].
70 Korthuis PT, Asch SM, Anaya HD, et al. Lipid screening in HIV-infected veterans. J Acquir Immune Defic Syndr. Mar 1. 2004;35(3):253-260. [pmid: 15076239].
71 Bennett CL, Horner RD, Weinstein RA, et al. Racial differences in care among hospitalized patients with Pneumocystis carinii pneumonia in Chicago, New York, Los Angeles, Miami, and Raleigh-Durham. Arch Intern Med. Aug 7–21. 1995;155(15):1586-1592. [pmid: 7618980].
72 Butt AA, Justice AC, Skanderson M, Rigsby M, Good CB, Kwoh CK. Rate and predictors of treatment prescription for hepatitis C. Gut. Sep. 27. 2006.
73 Butt AA, Justice AC, Skanderson M, Good C, Kwoh CK. Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects. Aliment Pharmacol Ther. Aug 15. 2006;24(4):585-591. [pmid: 16907891].
74 Cheung RC, Currie S, Shen H, et al. Chronic hepatitis C in Latinos: natural history, treatment eligibility, acceptance, and outcomes. Am J Gastroenterol. Oct. 2005;100(10):2186-2193. [pmid: 16181367].
75 Booth BM, Blow FC, Cook CA, Bunn JY, Fortney JC. Age and ethnicity among hospitalized alcoholics: a nationwide study. Alcohol Clin Exp Res. Dec. 1992;16(6):1029-1034. [pmid: 1335219].
76 Rosenheck R, Seibyl CL. Participation and outcome in a residential treatment and work therapy program for addictive disorders: the effects of race. Am J Psychiatry. Aug. 1998;155(8):1029-1034. [pmid: 9699689].
77 Ross R, Fortney J, Lancaster B, Booth BM. Age, ethnicity, and comorbidity in a national sample of hospitalized alcohol-dependent women veterans. Psychiatr Serv. May. 1998;49(5):663-668. [pmid: 9603573].
78 Stack K, Cortina J, Samples C, Zapata M, Arcand LF. Race, age, and back pain as factors in completion of residential substance abuse treatment by veterans. Psychiatr Serv. Sep. 2000;51(9):1157-1161. [pmid: 10970920].
79 Blow FC, Zeber JE, McCarthy JF, Valenstein M, Gillon L, Bingham CR. Ethnicity and diagnostic patterns in veterans with psychoses. Soc Psychiatry Psychiatr Epidemiol. Oct. 2004;39(10):841-851. [pmid: 15669666].
80 Kales HC, Blow FC, Bingham CR, Copeland LA, Mellow AM. Race and inpatient psychiatric diagnoses among elderly veterans. Psychiatr Serv. Jun. 2000;51(6):795-800. [pmid: 10828113].
81 Murdoch M, Hodges J, Cowper D, Fortier L, van Ryn M. Racial disparities in VA service connection for posttraumatic stress disorder disability. Med Care. Apr. 2003;41(4):536-549. [pmid: 12665717].
82 Kilbourne AM, Bauer MS, Han X, et al. Racial differences in the treatment of veterans with bipolar disorder. Psychiatric Services. Dec. 2005;56(12):1549-1555. [pmid: 16339617].
83 Kilbourne AM, Bauer MS, Pincus H, Williford WO, Kirk GF, Beresford T. Clinical, psychosocial, and treatment differences in minority patients with bipolar disorder. Bipolar Disord. Feb. 2005;7(1):89-97. [pmid: 15654937].
84 Owen RR, Feng W, Thrush CR, Hudson TJ, Austen MA. Variations in prescribing practices for novel antipsychotic medications among Veterans Affairs hospitals. Psychiatr Serv. Nov. 2001;52(11):1523-1525. [pmid: 11684751].
85 Charbonneau A, Rosen AK, Ash AS, et al. Measuring the quality of depression care in a large integrated health system. Med Care. May. 2003;41(5):669-680. [pmid: 12719691].
86 Valenstein M, McCarthy JF, Ignacio RV, Dalack GW, Stavenger T, Blow FC. Patient- and facility-level factors associated with diffusion of a new antipsychotic in the VA health system. Psychiatr Serv. Jan. 2006;57(1):70-76. [pmid: 16399965].
87 Kilbourne AM, Pincus HA. Patterns of psychotropic medication use by race among veterans with bipolar disorder. Psychiatr Serv. Jan. 2006;57(1):123-126. [pmid: 16399973].
88 Rosenheck R, Fontana A. Black and Hispanic veterans in intensive VA treatment programs for Posttraumatic Stress Disorder. Med Care. Jan. 2002;40(1 Suppl):I52-61. [pmid: 11789632].
89 Rosenheck R, Leda C, Frisman L, Gallup P. Homeless mentally ill veterans: race, service use, and treatment outcomes. Am J Orthopsychiatry. Oct. 1997;67(4):632-638. [pmid: 9361869].
90 Akpaffiong M, Kunik ME, Hale D, Molinari V, Orengo C. Cross-cultural differences in demented geropsychiatric inpatients with behavioral disturbances. Int J Geriatr Psychiatry. Oct. 1999;14(10):845-850. [pmid: 10521883].
91 Young AS, Sullivan G, Duan N. Patient, provider, and treatment factors associated with poor-quality care for schizophrenia. Ment Health Serv Res. Dec. 1999;1(4):201-211. [pmid: 11256726].
92 Rosenheck R, Fontana A. Utilization of mental health services by minority veterans of the Vietnam era. J Nerv Ment Dis. Dec. 1994;182(12):685-691. [pmid: 7989912].
93 Rosenheck R, Stolar M. Access to public mental health services: determinants of population coverage. Med Care. Apr. 1998;36(4):503-512. [pmid: 9544590].
94 Becerra RM, Greenblatt M. The mental health-seeking behavior of Hispanic veterans. Compr Psychiatry. Jan–Feb. 1981;22(1):124-133. [pmid: 7460561].
95 Greenberg GA, Rosenheck RA. Change in mental health service delivery among blacks, whites, and Hispanics in the Department of Veterans Affairs. Adm Policy Ment Health. Sep. 2003;31(1):31-43. [pmid: 14650647].
96 Grubaugh AL, Frueh BC, Elhai JD, Monnier J, Knapp RG, Magruder KM. Racial differences in psychiatric symptom patterns and service use in VA primary care clinics. Psychiatr Serv. Mar. 2006;57(3):410-413. [pmid: 16525003].
97 Kales HC, Blow FC, Bingham CR, Roberts JS, Copeland LA, Mellow AM. Race, psychiatric diagnosis, and mental health care utilization in older patients. Am J Geriatr Psychiatry. Fall. 2000;8(4):301-309. [pmid: 11069270].
98 Leda C, Rosenheck R. Race in the treatment of homeless mentally ill veterans. J Nerv Ment Dis. Aug. 1995;183(8):529-537. [pmid: 7643065].
99 Bosworth HB, Parsey KS, Butterfield MI, et al. Racial variation in wanting and obtaining mental health services among women veterans in a primary care clinic. J Natl Med Assoc. May. 2000;92(5):231-236. [pmid: 10881472].
100 Westermeyer J, Canive J, Thuras P, Chesness D, Thompson J. Perceived barriers to VA mental health care among Upper Midwest American Indian veterans: description and associations. Med Care. Jan. 2002;40(1 Suppl):I62-71. [pmid: 11789633].
101 Greenberg GA, Rosenheck RA. Changes in satisfaction with mental health services among blacks, whites, and Hispanics in the Department of Veterans Affairs. Psychiatr Q. Winter. 2004;75(4):375-389. [pmid: 15563054].
102 Rosenheck R, Fontana A, Cottrol C. Effect of clinician-veteran racial pairing in the treatment of posttraumatic stress disorder. Am J Psychiatry. Apr. 1995;152(4):555-563. [pmid: 7694904].
103 Koenig HG, Cohen HJ, Blazer DG, et al. Religious coping and depression among elderly, hospitalized medically ill men. Am J Psychiatry. Dec. 1992;149(12):1693-1700. [pmid: 1443246].
104 Dolan NC, Ferreira MR, Fitzgibbon ML, et al. Colorectal cancer screening among African-American and white male veterans. Am J Prev Med. Jun. 2005;28(5):479-482. [pmid: 15894152].
105 Fisher DA, Jeffreys A, Coffman CJ, Fasanella K. Barriers to full colon evaluation for a positive fecal occult blood test. Cancer Epidemiol Biomarkers Prev. Jun. 2006;15(6):1232-1235. [pmid: 16775188].
106 Etzioni DA, Yano EM, Rubenstein LV, et al. Measuring the quality of colorectal cancer screening: the importance of follow-up. Dis Colon Rectum. Jul. 2006;49(7):1002-1010. [pmid: 16673056].
107 Bosworth HB, Dudley T, Olsen MK, et al. Racial differences in blood pressure control: potential explanatory factors. Am J Med. Jan. 2006;119(1):70 e79-15. [pmid: 16431192].
108 Rehman SU, Hutchison FN, Hendrix K, Okonofua EC, Egan BM. Ethnic differences in blood pressure control among men at Veterans Affairs clinics and other health care sites. Arch Intern Med. May 9. 2005;165(9):1041-1047. [pmid: 15883244].
109 Woodard LD, Kressin NR, Petersen LA. Is lipid-lowering therapy underused by African Americans at high risk of coronary heart disease within the VA health care system?. Am J Public Health. Dec. 2004;94(12):2112-2117. [pmid: 15569962].
110 Williams ML, Morris MT 2nd, Ahmad U, Yousseff M, Li W, Ertel N. Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center. Ethn Dis. Winter. 2002;12(1):S1-58-62. [pmid: 11913623].
111 Fu SS, Sherman SE, Yano EM, van Ryn M, Lanto AB, Joseph AM. Ethnic disparities in the use of nicotine replacement therapy for smoking cessation in an equal access health care system. Am J Health Promot. Nov–Dec. 2005;20(2):108-116. [pmid: 16295702].
112 Ambriz EH, Woodard LD, Kressin NR, Petersen LA. Use of smoking cessation interventions and aspirin for secondary prevention: are there racial disparities?. Am J Med Qual. Jul–Aug. 2004;19(4):166-171. [pmid: 15368781].
113 Woodard LD, Hernandez MT, Lees E, Petersen LA. Racial differences in attitudes regarding cardiovascular disease prevention and treatment: a qualitative study. Patient Educ Couns. May. 2005;57(2):225-231. [pmid: 15911197].
114 Straits-Troster KA, Kahwati LC, Kinsinger LS, Orelien J, Burdick MB, Yevich SJ. Racial/Ethnic differences in influenza vaccination in the veterans affairs healthcare system. Am J Prev Med. 2006;31(5):375-382. [pmid: 17046408].
115 Bean-Mayberry B, Chang CC, Scholle SH. Brief report: lack of a race effect in primary care ratings among women veterans. J Gen Intern Med. Oct. 2006;21(10):1105-1108. [pmid: 16970560].
116 Washington DL, Harada ND, Villa VM, et al. Racial variations in Department of Veterans Affairs ambulatory care use and unmet health care needs. Military Medicine. Mar. 2002;167(3):235-241. [pmid: 11901574].
117 Washington DL, Villa V, Brown A, Damron-Rodriguez J, Harada N. Racial/ethnic variations in veterans’ ambulatory care use. American Journal of Public Health. Dec. 2005;95(12):2231-2237. [pmid: 16257951].
118 Sharkness CM, Snow DA. The patient’s view of hypertension and compliance. Am J Prev Med. May–Jun. 1992;8(3):141-146. [pmid: 1632999].
119 Braun UK, Rabeneck L, McCullough LB, et al. Decreasing use of percutaneous endoscopic gastrostomy tube feeding for veterans with dementia-racial differences remain. J Am Geriatr Soc. Feb. 2005;53(2):242-248. [pmid: 15673347].
120 Horner RD, Swanson JW, Bosworth HB, Matchar DB. Effects of race and poverty on the process and outcome of inpatient rehabilitation services among stroke patients. Stroke. Apr. 2003;34(4):1027-1031. [pmid: 12624220].
121 Hwang SS, Chang VT, Alejandro Y, et al. Study of hormone refractory prostate cancer: hospital care and palliative care resource use at a VA medical center. Cancer Invest. 2004;22(6):849-857. [pmid: 15641482].
122 Hwang SS, Chang VT, Cogswell J, Srinivas S, Kasimis B. Knowledge and attitudes toward end-of-life care in veterans with symptomatic metastatic cancer. Palliat Support Care. Sep. 2003;1(3):221-230. [pmid: 16594422].
123 Casarett DJ, Hirschman KB, Coffey JF, Pierre L. Does a palliative care clinic have a role in improving end-of-life care? Results of a pilot program. J Palliat Med. Jun. 2002;5(3):387-396. [pmid: 12150148].
124 Kressin NR, Boehmer U, Berlowitz D, Christiansen CL, Pitman A, Jones JA. Racial variations in dental procedures: the case of root canal therapy versus tooth extraction. Med Care. Nov. 2003;41(11):1256-1261. [pmid: 14583688].
125 Wei GS, Jackson JL, Herbers JE Jr. Ethnic disparity in the treatment of women with established low bone mass. J Am Med Womens Assoc. Summer. 2003;58(3):173-177. [pmid: 12948109].
126 Julapalli VR, Kramer JR, El-Serag HB. Evaluation for liver transplantation: adherence to AASLD referral guidelines in a large Veterans Affairs center. Liver Transpl. Nov. 2005;11(11):1370-1378. [pmid: 16184521].
127 Gordon HS, Johnson ML, Ashton CM. Process of care in Hispanic, black, and white VA beneficiaries. Med Care. Sep. 2002;40(9):824-833. [pmid: 12218772].
128 Arozullah AM, Ferreira MR, Bennett RL, et al. Racial variation in the use of laparoscopic cholecystectomy in the Department of Veterans Affairs medical system. J Am Coll Surg. Jun. 1999;188(6):604-622. [pmid: 10359353].
129 Groeneveld PW, Sonnad SS, Lee AK, Asch DA, Shea JE. Racial differences in attitudes toward innovative medical technology. J Gen Intern Med. Jun. 2006;21(6):559-563. [pmid: 16808736].
130 Flaherty JA, Naidu J, Lawton R, Pathak D. Racial differences in perception of ward atmosphere. Am J Psychiatry. Jun. 1981;138(6):815-817. [pmid: 7246814].
131 Young GJ, Meterko M, Desai KR. Patient satisfaction with hospital care: effects of demographic and institutional characteristics. Med Care. Mar. 2000;38(3):325-334. [pmid: 10718357].
132 Damron-Rodriguez J, White-Kazemipour W, Washington D, Villa VM, Dhanani S, Harada ND. Accessibility and acceptability of the Department of Veteran Affairs health care: diverse veterans’ perspectives. Mil Med. Mar. 2004;169(3):243-250. [pmid: 15080247].
133 Davis LE, Gelsomino J. An assessment of practitioner cross-racial treatment experiences. Soc Work. Jan. 1994;39(1):116-123. [pmid: 8310317].
134 Graveley EA, Oseasohn CS. Multiple drug regimens: medication compliance among veterans 65 years and older. Res Nurs Health. Feb. 1991;14(1):51-58. [pmid: 2017581].
135 Schneiderman AI, Lincoln AE, Curbow B, Kang HK. Variations in health communication needs among combat veterans. Am J Public Health. Dec. 2004;94(12):2074-2076. [pmid: 15569954].
136 Smith RP, Devine P, Jones H, DeNittis A, Whittington R, Metz JM. Internet use by patients with prostate cancer undergoing radiotherapy. Urology. Aug. 2003;62(2):273-277. [pmid: 12893334].
137 Basson MD, Gomez R, Fishman L, Panzini L. Informed consent for screening sigmoidoscopy in a Veterans Administration population. Dis Colon Rectum. Nov. 2004;47(11):1939-1946. [pmid: 15622589].
138 Gurmankin AD, Polsky D, Volpp KG. Accounting for apparent “reverse” racial disparities in Department of Veterans Affairs (VA)-based medical care: influence of out-of-VA care. Am J Public Health. Dec. 2004;94(12):2076-2078. [pmid: 15569955].