# ONGOING AND RECENTLY COMPLETED RESEARCH

Our environmental scan identified 43 ongoing or recently completed studies of racial disparities in VA populations, the results of which have not yet been published (Evidence Table 10, Appendix IV). Data available from these studies were primarily in abstract form and were thus not fully evaluable. We describe the content of those studies here.

Three studies are randomized controlled trials of intervention strategies to improve racial equity in healthcare. One study tests whether a decision aid video and motivational interviewing techniques improve willingness to consider knee replacement for osteoarthritis (Ibrahim SA). Another study examines whether the use of a plain-language decision aid among prostate cancer patients is effective for decision-making and interacting with physicians, and influences the receipt of active treatment (Fagerlin A). The third study is a physician-based intervention that employs computerized reminders and training on patient-centered counseling to improve communication with patients about hypertension medication use (Kressin NR).

Nineteen studies conducted/are conducting 1^st^-generation research to determine racial differences in indicators of utilization or quality, listed below by clinical topic (and indicating the number of studies):

Cardiovascular disease (2)

- The use of invasive cardiac procedures (Kressin NR; Urech TH)

Diabetes (4)

- Processes of care and intermediate outcomes (Bean-Mayberry B; Heisler M; Wright SM)
- The use of angiotensin converting enzyme inhibitors and angiotensin receptor blockers in patients with diabetes and hypertension (Barnett MJ)

HIV/Hepatitis C (2)

- Utilization of HIV screening (Owens D)
- Receipt of antiviral treatment for hepatitis C (Rousseau CM)

Mental health and substance abuse (3)

- Participation in treatment for PTSD (Spoont MR)
- Pharmacotherapy for bipolar disorder (Kilbourne AM)
- Validity of psychometric test data used in evaluation for PTSD (Boggs CD)

Palliative care (3)

- Deaths occurring in-hospital (Mularski RA)
- Utilization of aggressive medical treatments in end-of-life care (Yu W)
- Use of noninvasive vs. mechanical ventilation for COPD (Cannon KT)

Preventive care (2)

- Completion of FOBT screening (Fisher D)
- Use of pneumococcal and influenza vaccinations (Bean-Mayberry B)

Other topics (3)

- Use of procedures by hospital racial composition of patients (Groeneveld PW)
- 30-day mortality and outcomes by hospital racial composition (Jha AK)
- Diagnosis setting and treatment for epilepsy (Hope OA)

Potential mediators of racial disparities are investigated in 22 ongoing 2^nd^-generation studies:

Arthritis/pain management (5)

- Patient expectations regarding joint replacement (Groeneveld PW)
- Patient perceptions and willingness to consider joint replacement (Kwoh K)
- Patient referrals, acceptance, and satisfaction with joint replacement surgery, and the role of patient-physician communication (Ibrahim SA)
- Patient preferences and perceptions of physician's participatory decision-making style (Golightly YM)
- Provider decision-making for pain management in inpatient and outpatient settings (Crowley-Matoka M)

Cancer (1)

- Effect of health literacy, social support, and use of screening tests on stage of presentation for prostate, colorectal, and lung cancer (Arozullah AM)

Cardiovascular disease (4)

- Relationship of physician-patient communication to outcomes in chronic heart failure (Gordon HS)
- Recognition of stroke warning signs/symptoms and appropriate first action (Ellis C and Egede L)
- Physician's attitudes about race-based therapies—BiDil for congestive heart failure (Frank D)
- Interactions, views, and decisions of patients and providers regarding invasive v. noninvasive diagnosis and treatment of ischemic heart disease (Siminoff LA)

Diabetes (2)

- Trust in physicians and distrust of health care systems, in relation to personal health practices and outcomes (Egede LE)
- Barriers to glucose control (Shacter HE)

Mental health and substance abuse (4)

- Impact of 2002 policy increase in prescription copayment on medication use and psychiatric admissions for schizophrenia (Zeber JE)
- Perceptions of the trust and satisfaction with healthcare environment in relation to medication adherence in bipolar disorder (Zeber JE)
- Severity of psychiatric disorders and readiness for change at initiation of psychiatric treatment, and satisfaction with treatment after 6 months (Tiet QQ)
- PTSD service connection (receiving vs. not receiving disability benefits) and long-term outcomes, including symptom severity, social adjustment, functioning, income, employment, health care utilization and costs, homelessness, and mortality (Murdoch M)

Preventive and ambulatory care (4)

- Patient factors in colorectal screening behavior including knowledge, values and preferences, and stage of readiness (Partin MR)
- Physician-patient communication in engaging patients in hypertension management and adherence (Bokhour B)
- Associations between patient race, experiences with clinicans, attitudes and beliefs about hypertension and medication adherence (Kressin NR)
- Examines dual utilization of VA and Indian Health Services among AIAN veterans to identify barriers, fragementation and overlap of services (Kramer B)

Other areas (1)

- Factors (e.g. insurance, income, caregiver distress, social support, distance) that affect hospitalizations for ambulatory care sensitive conditions such as diabetes and hypertension, among community-residing veterans with dementia (Van Houtven CH)