# METHODS

The review consisted of two components: a review of the existing literature reporting the findings of research on racial disparities within the VA, and an environmental scan of ongoing or recently completed studies of racial disparities within the VA.

## Literature Search and Strategy

We conducted a search in Medline (via PubMed) and HealthSTAR of literature published from 1966 to October 9, 2006. The search terms and MeSH headings included the following: VA, veteran(s), United States Department of Veterans Affairs, ethnic, race, racial, disparity(-ies), black(s), Hispanic, population groups, race relations. Appendix I provides the strategy and search terms in detail. All citations were imported into an electronic database (EndNote 9.0)

The search strategy was saved in the PubMed database to provide weekly automatic updates on new publications. We obtained additional articles from reference lists of pertinent studies, and by consulting authors of retrieved studies, our technical expert advisory group, and other known VA disparities researchers. We searched the Health Services Research Projects database to identify ongoing and recently completed VA research projects.

## Eligibility Criteria and Study Selection

Two reviewers assessed for relevance the abstracts of citations identified from literatures searches, using the criteria described in Appendix II. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria.

Eligible articles had English-language abstracts and provided primary data relevant to the key questions. We included studies that were conducted within the VA or with VA beneficiaries, reported outcomes of interest by veteran race and/or ethnicity. Outcomes of interest included on utilization of health care services; quality of health care services including quality metrics (e.g. blood pressure control), process-of-care measures (e.g. use of appropriate screening tests), patient evaluations of care, and direct observations of care (e.g. communication patterns); and potential mediators of disparities in utilization or quality at various levels (system, provider, or patient). We further selected studies that focused on race—or “patient characteristics” (including race)—as the variable of interest, as indicated in the title or stated objectives of the study. We excluded studies that met other inclusion criteria but that were not specifically focused on comparisons by race or patient characteristics in general, to avoid potential publication bias. In an early assessment, we found that studies reporting comparisons by race despite not indicating those comparisons as part of their study objectives were substantially more likely than race-focused studies to report racial disparities to be present. These “non-race-focused” studies therefore skewed the overall assessment of the degree and distribution of disparities within the VA, since they might not have reported on racial comparisons had disparities not been found.

## Data abstraction and quality assessment

We abstracted the following data from included studies: study design, objectives, setting, population characteristics (including sex, age, ethnicity, diagnosis), subject eligibility and exclusion criteria, number of subjects, race/ethnic groups compared, methods of outcome assessment, data sources for race/ethnicity and outcome data, analytic method, potential confounders adjusted for in the analysis, and the results for each outcome.

Because the studies were heterogeneous in design, objectives, and outcomes, we did not systematically rate the validity of individual studies. We instead assessed the level of adjustment for potential confounders and whether race/ethnicity data was gathered by self-report, and considered these indicators in the qualitative synthesis of evidence.

## Evidence Synthesis and Data Presentation

We constructed evidence tables showing the study characteristics and results for all included studies, organized by clinical topic. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each clinical topic and drew conclusions based on qualitative synthesis of the findings. After summarizing the findings for each clinical topic, we synthesized the descriptions and summaries of the literature for each clinical topic to derive a set of “cross-cutting” themes related to the underlying causes of healthcare disparities. These served as the basis for a proposed set of potential interventions for future research aimed at reducing racial disparities in VA health care.

## Environmental Scan

The environmental scan was intended to capture ongoing or recently completed (but unpublished) studies related to racial disparities within the VA. To accomplish this task, we communicated with the HSR&D Center for Health Equity Research and Promotion and consulted with established disparities researchers within the VA, including our technical expert advisory group. We searched the VA HSR&D website for currently and recently funded disparities studies to identify ongoing or recent intervention studies. Finally, we reviewed abstracts from the 2006 and 2007 VA HSR&D Annual Meeting for relevant studies. We compiled an evidence table of all relevant completed but unpublished studies.