# EVIDENCE TABLES

EVIDENCE TABLE 1 VA-BASED STUDIES OF RACE AND QUALITY OF CARE FOR PAIN AND ARTHRITIS

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Race/ethnic groups compared | Incl/Excl criteria | Source of race data | Type of outcome: describe | Analytic method | Outcome data source/methods of outcome assessment | Variables adjusted for in analysis | Characteristics of study pop | Results, describe qualitatively | Comments
Allen, 2006 | Pilot study of pain and coping among patients with osteoarthritis: a daily diary analysis | To examine pain and coping strategy use among white and nonwhite veterans with OA, using a daily diary approach; to examine pain severity, pain variability, coping strategy use, and the relationships among these variables. | Cross-sectional survey | 36 | Durham VAMC | Nonwhite v. white | Patients were identified by diagnosis of OA in electronic medical records. Individuals with an upcoming clinic appointment were identified so that an in-person survey could be conducted in conjunction with the visit. 36 completed the study. | Self-report via daily diary | Diaries of self-reported pain (10-cm visual analog scale) and copoing (total, problem-focused, and emotion-focused) for 30 days. CSQ asks pts to rate their frequency of use of 48 coping strategies on a 7-pt likert scale ranging from never to always. VAS; also Stone and Neale’s Daily Coping Inventory adapted for pain coping - asks pts to indicate whether they have used 7 specific activities or thought processes to cope with OA pain: direction action to reduce pain, relaxation, distraction, redefinition of pain, venting emotions, seeking spiritual comfort, and seeking emotional support. Factor analysis identified 2 coping factors from this scale: problem-focused and emotion-focused coping. | ACF (autocorrelation function) for the 30-day period; generalized linear mixed models (GLMM) were used to model presence of emotion-focused coping over time; correlations of the CSQ with mean pain severity and variabilty from the diary VAS. | Self-report. Participants first completed a baseline survey including demographic info and the Coping Strategies Questionaire (CSQ). Pts were then given paper diaries and asked to complete 1 diary entry per day just before sleeping, for 30 days. Pts were instructed to mail back diaries the day after completion using prepared stamped envelopes. Each diary included a standard 10-cm pain VAS, scored on a scale of 0 to 10, and also Stone and Neale’s Daily coping Inventory | Unclear | 89% male 55% had hand OA 48% had hip OA 48% had back OA mean age 63 23 white 13 nonwhites: 12 blacks, 1 Hispanic | Racial differences in total coping and problem-focused coping scores were minimal. Nonwhites had higher emotion-focused coping socres than whites (means 1.43 v. 0.86, scale 0–4) though not to significance. For whites, there was a positive relationship of problem-focused coping with pain, and the converse was observed for nonwhites. | Small sample size (12 blacks + 1 Hispanic)
Ang, 2002 | Ethnic differences in the perception of prayer and consideration of joint arthroplasty | to examine ethnic differences in the perception and use of prayer in the treatment of arthritis and its role in patients’ decision making toward surgery | Cross-sectional survey | 596 | Primary care clinics at Cleveland VAMC | black v white | Patients attending the primary care clinics at Cleveland VAMC were screened for presence of chronic knee or hip pain, extent of interference with daily functioning. Eligible patients were self-identified blacks or whites, aged 50+, who had no history of knee or hip arthroplasty, and reported a history of hip or knee pain of at least moderate severity (5+ on the Lequense Osteoarthritis Severity Index). Referral for surgical evaluation is considered reasonable if this score >10. | Self-report, by interviewer-administered questionnaire | Patient’s perceptions of the role of prayer in the management of arthritis | Multivariate logistic regression | Perceptions of prayer and consideration of surgery were gathered by interviewer-administered questionnaire. Role of prayer in mgmt of arthritis was based on the Efficacy of Specific Treatment Questionnaire, which assessed both how helpful they considered prayer for their arthritis and whether they had used prayer to treat their arthritis. Willingness to undergo arthroplasty was assessed by the question, “if your hip/knee pain were ever to get severe, would you consider surgery to replace your hip/knee if your doctor recommended it? Medical records were reviewed for the presence of 13 other diagnoses using Charlson Comorbidity Index. Patients were also screened for depression using the Geriatric Depression Scale. Religiosity scale incl. how religious do you consider yourself, how often do you attend religious services, how important in general is religion to you, how frequently do you pray | age, marital status, educational level, WOMAC score, geriatric depression score | Men with osteoarthritis 44% black 56% white Religious denomination, black v. white: Baptist 57% v 9.4% Catholic 3.4% v 33.6% Other Protestant 26.7% v 41.5% Muslim or Jewish 12.5% v 13.2% | Blacks and whites were similar in age, WOMAC score, Lequense severity score, geriatric depression score, and Charlson comorbidity score. Blacks had lower SES and fewer high school graduates (57.4% v 71%), lower levels of employment (8.4% v 14.7%), and lower total household incomes, and fewer blacks were married (39.2% v 55.6%). Blacks had higher religiosity than whites (77 v 70, p=0.001, and were more likely to perceive prayer as helpful (86.7% v 73.9%, p=0.0001) and to have actually tried prayer (74% v 56.6%, p=0.0001). Blacks remained more likely than whites to perceive prayer in the adjusted model: OR 2.1, 95%CI 1.19–3.72). Blacks were less likely than whites to consider arthroplasty as an option, after adjustment for confounders: 0.585, 95%CI 0.345–0.993. When stratifying by perception of prayer, significantly fewer blacks (79.3% v 86.2% of whites, p=0.02) would consider surgery among those who perceived prayer as helpful. Among those who considered prayer to be not helpful, there were no ethnic differences in the consideration of surgery. Ethnicity became no longer significant when helpfulness of prayer was included in the model. I.e. helpfulness of prayer remained a significant negative predictor of consideration of surgery, regardless of ethnic background (OR 0.64, 95%CI 0.43–0.94). | Blacks were more than twice as likely as whites to perceive prayer as helpful in the management of arthritis. Differences in cultural attitudes/perceptions toward prayer may partly explain the differential rates of arthroplasty between black patients and white patients. Study is limited for not having data on actual use of surgery: consideration of surgery was a hypothetical question that may not reflect actual behavior. Author suggests future research to follow patients prospectively to determine utilization of surgery.
Ang, 2003 | Is there a difference in the perception of symptoms between african americans and whites with osteoarthritis? | To determine if there is a difference in the perception of pain and functional disability between African Americans and Whites at any given radiographic severity of osteoarthritis. | Cross-sectional survey | 596 interviewed; 558 had joint films available | See Ang, 2002 | black v white | See Ang, 2002. Knee and hip radiographs were blindly read and graded using the Kellgren-Lawrence grading system, and confirmed using Atlas of Standard Radiographs was used to grade the severity of the individual radiographic features of OA. | Self-report, by interviewer-administered questionnaire | Self-administered WOMAC-pain and WOMAC-function were primary outcome measures. A 10-point difference in WOMAC (range 0–100) is considered clinically meaningful. | Multiple linear regression | Self-administered WOMAC-pain and WOMAC-function were primary outcome measures. A 10-point difference in WOMAC (range 0–100) is considered clinically meaningful. | Age, education, income, employment, marital status, BMI, Lequesne severity index, GDS, and Charlson comorbidity index. The interaction of ethnicity and radiographic severity was examined, as was collinearity among SES variables. | Men with osteoarthritis 44% black (n=262) 56% white (n=334) Mean age 65.6 | Ethnicity was not significantly associated with radiographic features of OA in either the hip or the knee joint. Blacks and whites had similar unadjusted mean scores for WOMAC-pain and WOMAC-function for either knee or hip OA, when stratified by radiographic features. After controlling for covariates, ethnicity was not a significant predictor of WOMAC- pain or function. Education (beta −0.107, p=0.018) and depression (0.188, p<0.00005) remained important predictors of pain, while depression (beta 0.298, p<0.00005) and BMI (beta 0.104, p=0.025) emerged as important predictors for function. | In a cross-sectional survey of elderly male veterans with chronic knee or hip pain, blacks and whites perceived the same degree of pain and functional difficulties of each strata of radiographic severity of OA. There was no ethnic difference in the perception of symptoms regardless of clinical OA severity as defined by Lequesne index.
Dominick, 2003 | Racial differences in health care utilization among patients with osteoarthritis | To examine racial differences in 2 components of OA related medical care among veterans: physician visits including specialty services, and prescription medication use between between African American and white veteran outpatients with OA. | Retrospective cohort study | 2473 | Durham VAMC | Black v. white | Black and white patients who had a physician visit involving OA at the Durham VAMC btw 1998–1999 (n=2473). Excluded 19% of patients with missing race data. Also excluded patients of Asian, American Indian, or Hispanic origin. Subjects missing race data significantly differed in that they were younger, % fewer female, and less likely to be disabled due to service-connected illness, and had a lower number of OA visits and were less likely to have any OA visit during the followup period. | Administrative records: Durham VA electronic medical records | Pts were followed for 1 year following the first OA related physician visit occurring within the study period. visits to physicians or rheumatologists; use of analgesic and antiinflammatory medications (total prescriptions in 1 year, drug class, annual mean days’ supply). | Multivariate regression | Durham VA electronic medical records | age, sex, service connection, and prior arthroplasty | Mean age 61.1; 57.2 among blacks, 63.2 among whites (p<0.001) 5% had undergone arthroplasty within 5 yrs prior 35% black (n=861) 65% white (n=1612) 19% missing race data | Blacks and whites were similar in the odds of having a physician visit or a rheumatology clinic visit. The number of annual OA related physician visits was similar by race. The adjusted odds of visiting an orthopedic clinic were significantly lwoer for blacks: OR 0.72, 95%CI 0.56–0.94. Blacks and whites were similar in the proportion (86%) who were prescribed any analgesic or antiinflammatory medication during 1-yr followup. Unadjusted use of nonselective NSAIDS was higher among blacks than whites: 69.1% v 50.3%, p<0.001. Use of COX-2 inhibitors was lower among blacks: 4.1% v 7.4%, p<0.001. Use of narcotic analgesics was lower among blacks: 32.6% v 40.1%, p<0.001. Use of acetaminophen (29–32%) and aspirin (2.5–3.1%) did not significantly differ by race. In a multivariate analysis, blacks were more likely than whites to use acetaminophen: OR 1.45 (95%CI 1.20–1.76) and nonselective NSAIDs 1.26 (1.04–1.53). Blacks were less likely to use COX-2 inhibitors 0.56 (0.38–0.83) and narcotic analgesics 0.67 (0.56–0.80). Blacks filled a significantly lower mean number of prescriptions than whites (blacks 3.1 v whites 3.7, p<0.001), and this remained significant after adjustment for covariates, despite that the mean N of different drugs was similar by race: 1.8 | Black and white patients with OA utilized physician visits similarly but had some differences in prescription medication use. Blacks’ greater use of nonselective NSAID and shorter duration of use for some medications suggest that blacks may be at increased risk for both adverse GI effects and inadequate pain relief. No interventions were suggested. Authors suggested further research to explore racial differences in the duration of medication use; blacks may have experienced less symptom reduction, encountered more side effects, or had a stronger preference for using non-pharmacological treatments.
Dominick, 2004 | Patterns of opioid analgesic prescription among patients with osteoarthritis | To examine the 1-year incidence of opioid analgesic prescriptions among veterans with a diagnosis of osteoarthritis (OA); to examine aspects of opioid prescription including N of prescriptions, duration of use, and dosing, and demographic factors. | retrospective cohort study | 3061 (2479 analyzed) | Durham VAMC | Black v. white | Subjects were Durham VAMC patients who had a physician visit involving OA btw 1998–1999, identified by ICD-9 code 715 using the hospital’s electronic medical record system. Included subjects with service-connected status; service- connected disability defined as occurring because of injury or disease that incurred or was aggravated during military service and does not bill for treatment of these conditions. | oupatient files (19% missing race data) | Opioid analgesic prescriptions were assessed for 1 year following the 1st OA-related physician visit occurring within the study period. Opioids in the VA formulary: oxycodone, oxycodone+acetaminophen, codein+acetaminophen, propoxyphene, and hydrocone+acetaminophen. Outcomes: any opioid use; N Rxs; N Rx per opioid; total annual days’ supply; range and mean daily dose calculated according to morphine equivalent doses where available (not for hydrocodone or propoxyphene). | Multivariate logistic regression | Drug data: electronic medical records. | Demographic variables: age, gender, and whether the veteran had a service connected health condition or disability | Diagnosed with OA 96% male mean age 60 28% black (n=857) 53% white (n=1622) <1% other race 19% missing race data 75% had service- connected health conditions or disabilities | In bivariate analyses, blacks were less likely than whites to be prescribed an opioid: 39% of blacks v. 47.3% of whites (p<0.001) received an opioid during 1-yr followup In multivariate analysis adjusted for demographic variables, with whites as reference, the OR for opioid prescription among blacks was 0.68 (95%CI 0.58–0.82, p<0.001). Among patients prescribed opioids, blacks received a lower annual days’ supply compared with whites: in bivariate analysis, mean annual days’s supply was 116.2 for whites, 85.2 for blacks (p<0.001). In multivariate analysis, Beta = −0.141 (p<0.001). Morphine equivalence dose was caluclated for 991 subjects. In multivariate analyses that adjusted for age, female gender, and service connection, black race was not significantly associated with minimum or average morphine equivalent dose. Race remained a significant predictor of maximum morphine equivalent dose: Beta = −0.079, p=−0.026. Average daily doses prescribed for all opioid drugs were below the recommended daily dose range for the treatment of OA; may be related to age since older adults have greater risk for AEs with higher doses. | Blacks were less likely to be prescribed an opioid than whites. Mean annual days’ supply of opioids and the maximum morphine equivalent dose were lower among blacks. Mean daily doses were below the recommended daily dose range for OA, for all opioid drugs. (This pattern argues against dose escalation that may indicate opioid addiction.) Intervention suggested by investigators: there may be a need fo additional physician education regarding the safety of opioids at doses recommended for OA. Research has shown that prescribing of analgesics at sub-optimal doses commonly results in inadequate pain amelioration(ref 25) and may expose individuals to the potential for adverse side effects while failing to provide proper symptom management. Mechanisms for disparities were not studied, but proposed explanations include 1) physicians may be more concerned about addiction or dependence with black patients, and 2) blacks and Hispanics with cancer expressed a belief in stoicism, concerns about addiction to opioids, a reluctance to complain about pain, and difficulties in communicating about pain (ref 35).
Dominick, 2004 | Racial differences in analgesic/anti-inflammatory medication use and perceptions of efficacy | To examine whether black and white vets with OA differed in their perceptions of the helpfulness of their current analgesic and anti-inflammatory medications. Perceptions of medication efficacy reflect adequacy of pain control and may also contribute to medication adherence. | cross-sectional survey | 202 | Durham VAMC | black v. white | Patients with OA at the Durham VAMC, and patients with an upcomoing clinic appointment so that the in-person survey could be conducted in conjunction with the visit. Analysis included black and white veterans. | Self-report | Pts rated the helpfulness of current analgesic/anti-inflammatory medications (scale: 1= not at all helpful to 10=very helpful). The in-person survey asked about arthritis symptoms, treatments (any use of Rx or OTC analgesic/anti-inflammatory drugs, specific drug categories (acetaminophen/traditional NSAIDS, COX-2 selective NSAIDS, opioids), and perceptions of helpfulness about these treatments. | bivariate and multivariate analyses; 2-level ANOVA for primary analysis | Self-report: in-person survey | arthritis severity (WOMAC), age, general health (poor to excellent), education level (no college v. some college or more), years of arthritis symptoms, number of joints affected by OA, number of arthritis drugs currently being taken (1–3), and the classes of the drugs being taken. | 91% male 30.2% black (n=61) 69.8% white (n=141) | In bivariate analyses, there were no significant differences in the proportion of blacks and whites using any of the drug categories. 22% of whites and 24.6% of blacks were not using any drugs. Among the remaining 156 subjects using analgesic/anti-inflammatory drugs, mean rating of drug helpfulness on a scale of 1–10 was higher among blacks (6.57) than among whites (5.94). In the multivariate analysis, the relationship of black race to medication helpfulness approached significance (t statistic = 1.91, p=0.05). Blacks also had higher self-reported OA severity: mean WOMAC score 54.6 v 48.4, p=0.02. Individuals with a WOMAC score >=39 are considered candidates for joint replacement surgery. In the multivariate analysis, WOMAC score was associated with lower medication helpfulness: 5 statistic −3.52 (p<0.001). | Blacks rated their current analgesic and anti-inflammatory drugs as being more helpful than did whites (6.57 v. 5.94), despite reporting greater OA symptoms (WOMAC). Perceptions of medication efficacy in the total sample did not differ between acetaminophen (mean score of 5.51 on a 1–10 scale) and NSAIDs (5.93), but both COX-2 inhibitors (6.77) and opioid analgesics (6.64) were rated as more helpful than acetaminophen. Authors note the limitation that patients’ adherence to specific drugs was not assessed, and that adherence may influence perceived efficacy. No interventions suggested by authors.
Dominick, 2004 | Racial/ethnic variations in non- steroidal anti-inflammatory drug (NSAID) use among patients with osteoarthritis | To examine patterns of NSAID use among patients with OA who were new NSAID users within the VA system; to examine racial differences in the initial type of NSAID prescribed, the N of prescriptions filled, the days’ supply, total time to discontinuation of the index NSAID, and NSAID switching. | retrospective cohort study | 6038 | National sample | black, Hispanic, white | All VA patients nationwide who newly began NSAID therapy in January 2000. All patients with new NSAID prescriptions (i.e. had no NSAID prescriptions for 12 months prior to the study) in this month were followed through June 2000. | Electronic: PTF and OPC | Subjects were new NSAID users with OA. Outcomes were types of NSAID prescribed: 1) COX-2 selective, 2) preferentially COX-2 selective, 3) non- selective (equally COX-1 and COX-2 selective), or 4) preferentially COX-1 selective; duration of NSAID use, i.e. days’supply of initial prescription; time to discontinuation of the index NSAID; NSAID switching. | Multivariate analyses | PBM, PTF, OPC | age, comorbidities (using Charlson score), history of GI bleeding or peptic ulcer disease diagnosed in the previous year, use of anticoagulants and oral glucocorticoids in the month prior to the study; sex; region; occurrecne of adverse GI events during NSAID use recorded in PTF & OPC files. Significance was set at p=0.01. | 33% missing race data in PTF or OPC, analyzed separately 0.7% Asian; excluded from analysis 11% black 3% Hispanic 56% white | COX-2 selective and preferentially COX-2 selective NSAIDs were prescribed less often among blacks (8.95%, 12.1%) and Hispanics (7.3%, 6.3%) than whites (10.2%, 16.7%). Non-selective or preferentially COX-1 selective NSAIDs were prescribed more often among blacks (79%) and Hispanics (86.4%) than whites (73.1%). Adjusting for covariates, Hispanics were less likely than whites to be prescribed drugs that were COX-2 selective or preferentially COX-2 selective: OR 0.47, 99%CI 0.27–0.83, p<0.001. Blacks were less likely than whites but not to significance: OR 0.79, 99%CI 0.60–1.04, p=0.028. Mean days’ prescribed supply was significantly higher (p<0.01) among whites (42.9 days) than among blacks (37.5) and Hispanics (31.3). The difference persisted (p<0.001) after controlling for covariates related to risk for GI events, and the category of NSAID prescribed. Mean time to discontinuation was longest among whites (104.2 days) followed by Hispanics (91.4) and blacks (90.5); a significant difference persisted only among blacks after adjustment for covariates. NSAID switching was not significantly different by race in multivariate analysis. | Ex vivo studies have indicated that NSAIDS with greater COX-2 selectivity are associated with lower risk for GI toxicity. Hispanics were less likely to be prescribed NSAIDS with some degree of COX-w selectivity, including newer agents (celecoxib and rofecoxib). Both blacks and Hispanics were prescribed NSIDS for fewer days at initiation, even controlling for GIF risk factors and the type of drug prescribed. Blacks filled fewer prescriptions for the index NSAID than white patients, and had a greater risk of NSAID discontinuation. There were no significant racial differences in whether patients switched NSAIDs. Author suggests the possibility that newer, more expensive COX-2 inhibitors are overutilized among white patients with a low risk for GI bleeding. Author suggests further resesarcher involving patient-level survey data to examine possible reasons for racial differences in discontinuation, including health literacy and adherence to prescription instructions.
Dominick, 2005 | Racial differences in analgesic/anti-inflammatory medication adherence among patients with osteoarthritis | 1) to describe the frequency of self-reported nonadherent behaviors; 2) examine whether self- reported adherence differs between black and white veterans, and 3) examine racial differences when controlling for other factors that may influence medication adherence, including demographic characteristics, arthritis severity, side effects, and participatory decision making. | cross-sectional survey | 156 | Durham VAMC | black v. white | Patients of the Durham VAMC with a diagnosis indicationg OA in electronic medical records; also identified patients with an upcoming clinic appointment so that the in-person survey could be conducted in conjunction with the visit - patients were recruited by phone before their clinic visit. Analysis included black and white veterans. | Self-report | 3 items in the survey (agree v. disagree) 1) I sometimes forget to take my arthritis medicine; 2) I am sometimes careless about taking my arthritis medicine; 3) When I feel better, I sometimes stop taking my arthritis medicine. A 3-item composite adherence measure = positive response to 1 of the 3 items. A 2-item composite adherence measure = positive response to 1 of the first 2 items. | bivariate relationships, multivariate logistic regression for composite adherence outcome | Self-report: in-person survey | Age, sex, marital status, education, arthritis severity using the Western Ontario McMaster Universities Osteoarthritis Index (WOMAC), participatory decision making (PDM), and side effects from current arthritis medication. Higher PDM score reflects the physician being more likely to involve the patient in treatment decision-making. | 90% male mean age 63 overall; blacks mean age 58, whites 64 (p=0.004) 35% black (n=55) 65% white (n=101) | Non-adherence was high overall: 44% of pts reported at least one nonadherent behavior related to OA medications. No significant racial differences were found in any of the individual adherence items or either of the composite measures, although greater proportions of blacks agreed with each of the items. % for each item, black v. white: sometimes forget to take medications, 31 v 22; sometimes careless about taking medications 20 v 13; sometimes stop taking medications when I feel bettere 31 v 24. In the multivariable logistic regression model for the 3-item compsite adherence measure (positive response to 1 of the 3 items) blacks were significantly more likely to report nonadherent behavior than whites: OR 2.25, 95%CI 1.03–4.91 (p=0.42). Individuals with greater PDM scores were less likely to report adherence OR 0.95, 95%CI 0.91–0.99 (p=0.039). In bivariate analyses, the nonadherent group had a greater proportion of blacks and have lower PDM scores, although there were no significant racial differences were found in education level, arthritis severity, participatory decision making, or reports of side effects. | Blacks had significantly greater odds of overall adherence (i.e. a positive response to any of the 3 items) in a model that adjusted for other demographic factors, disease severity, participatory decision making, and medication side effects. No sig. racial differences in PDM were observed, and racial differences in adherence persisted after adjusting for PDM. Greater levels of PDM were associated with reduced odds for nonadherence. The authors refer to a study of computer-based intervention aimed at enhancing patient involvement in decisions regarding analgesic/anti-inflamm med use. This intervention resulted in increased levels of appopriate medication use, as well as improvements in medication knowledge, realistic expectations of drug benefits, and ease of adherence. This intervention could enhance PDM and medication adherence across many chronic illnesses.
Golightly, 2005 | Racial variations in self- reported osteoarthritis symptom severity among veterans | to examine factors related to OA symptom severity in African American and Caucasians veterans; see Dominick 2004 | cross-sectional survey | 202 | Durham VAMC | Black v. white | See Dominick 2004, #1548 | Self-report | OA symptom severity per WOMAC score | Bivariate analyses and multivariate logistic regression | Self-report: in-person survey | age, gender, income, educational level, employment status, marital status, number of years with OA symptoms, location of arthritic joints (hip, knee, back, foot/ankle), use of exercise, and current use of OA medications | See Dominick 2004, #1548 | Blacks had higher scores than whites on both the WOMAC pain subscale (means 11.4 v. 9.8) and the function subscale (means 38.2 v 34.3). In the multivariate regression model, blacks had significantly greater total WOMAC scores than whites (Beta = 0.185, p=0.009). In within-race analyses (included only 1 race), among whites the following were associated with greater WOMAC: greater # years with OA, presence of hip OA, and low income. Among blacks, factors associated with greater WOMAC score included no use of exercise, and presence of back or hip OA. | A WOMAC score greater than 39 indicates symptoms severe enough to be considered a candidate for arthroplasty. WOMAC scores were 6.5% higher (6.2 points) among blacks, which approaches the minimal clinically important difference reported in interventional studies. In multivariate models, race explained 18.5% (beta = 0.185) of the difference in total WOMAC scores. Authors note that these results differ from studies by Jordan 2003 (non- veteran pop) and Ang 2003 (included in review) which examined pain in only one specific joint, whereas this study (Golightly 2005) measured more general OA symptom severity in the back and lower extremities.
Ibrahim, 2001 | Variation in perceptions of treatment and self-care practices in elderly with osteoarthritis: a comparison between African American and white patients | To compare elderly African American and white patients with osteoarthritis of the knee or hip with respect to their perceptions of the efficacy of traditional and complementary treatments and their self-care practices. | Cross-sectional survey | 593 | Data from a VA study of ethnic and cultural variations in management of osteoarthritis | Black v. non- Hispanic white | 1,351 male patients attending the primary care clinics of Cleveland VAMC between 1997–2000 were randomly approached by trained interviewers. Patients were asked qeustions about presence, duration, and severity of hip or knee pain, from NHANES survey. Eligible patients reported moderate to severe pain for >6 months (per Lequesne scale) and age 50+. 776 eligible, 83 refused to participate. This report analyzes the first 593 patients to complete the study. Excluded patients who had already had knee or hip replacement. | Self-report by structured questionnaires | Major outcome measure: self-care questionnaire, “If your hip/knee pain were to be come severe, would you do the following?” Options: take OTC medicine, ask a friend or family for advice, cut down on activities, and rub on medicated cream. Also asked if they would seek care from a chiropractor or physical therapist: yes/no. Also asked perceptions of efficacy of aspirin, tylenol, visits to medical doctor, physical therapy, prescribed meds, knee or hip replacement therapy, herb al medicine, massage, prayer, use of copper or other metal bracelets, heat, NutraJoint, and shark cartilage as forms of treatment (helpful or not helpful). WOMAC; Geriatric Depression Scale; Charlson Comorbidity Index. | Multivariate logistic regression | Interviewer-administered questionnaires; medications comorbidity and health care utilization gathered from VA database; all subjects had hip or knee x-rays. | Age, disease severity or functional status, socioeconomic status (educational level and household annual income), and Geriatric Depression Scale score. | Males with moderate to severe knee/hip pain 261 black 332 white | Adjusted OR (95%CI), black v. white, responses to self-care questions: Use of OTC medicine: 1.76 (1.14–2.72) Ask a friend or family for advice: 2.11 (1.44–3.07) Cut down on activities: 2.22 (1.28–3.85) Apply a medicated cream: 2.27 (1.38–3.73) Responses to questions on perceptions of efficacy of specific treatments: Traditional care: Physical therapy: 1.99 (1.16–3.44) Knee/hip replacement: 0.52 (0.28–0.98) Tylenol: 2.15 (1.26–3.65) Complementary care: Herbal medicine: 1.71 (1.11–2.63) Massage: 2.54 (1.48–4.37) Prayer: 1.93 (1.19–3.14) Copper/metal bracelet: 1.67 (1.07–2.60) NutraJoint: 1.64 (1.02–2.51) When asked about actual use of these forms of treatment, there was no significant difference between the race groups except for prescribed medication use (black v. white: OR 1.67, 95%CI 1.14–2.44), massage (1.44, 95%CI 1.03–2.01), and prayer (OR 2.19, 95%CI 1.54–3.11). The adjusted OR (95%CI, black v. white) for perceptions on the efficacy of chiropractic care was 3.23 (2.17–4.83). However, blacks were significantly less likely than whites to report actual use of chiropractice care for their knee or hip osteoarthritis; OR 0.47 (0.29–0.75). | Blacks were more likely to answer “yes” to questions about using OTC meds, asking friends or family for advice, cutting down on activities, and applying a medicated cream, seeking advice or care from a chiropractor or physical therapist. Blacks were more likely than whites to perceive the following treatments as helpful: Tylenol, physical therapy, use of herbal medicine, massage, prayer, use of NutraJoint, use of copper or other metal bracelets. Blacks were less likely to perceive knee/hip replacement as helpful. Blakcs were more likely than whites to believe that prayer and other forms of “complementary care” were helpful in the treatment of osteoarthritis. Blacks were also more likely to indicate reliance on self- care elements in the management of arthritis. Blacks were less likely than whites to perceive joint replacement therapy as efficacious. Authors suggest that these findings may partially explain the observed racial differences in utilization of joint replacement for osteoarthritis of knee and hip, noting that this study was not designed to test this specific hypothesis. Authors suggest the development of innovative programs that are culturally appropriate and congruent with patient values, attitudes, and beliefs.
Ibrahim, 2002 | Differences in expectations of outcome mediate African American/white patient differences in “willingness” to consider joint replacement | To determine whether African American patients differ from white patients in their “willingness” to consider joint replacement and to determine the factors that influence this relationship. | Cross-sectional survey | 596 | Primary care clinics | black v white | See Ang, 2002. Same study population as Ibrahim 2002, Ang 2002, and Ang 2003. This report provides the additional result on “willingness” to consider JR. | Self-report, by interviewer- administered questionnaire | “Willingness” to consider joint replacement | Multivariate logistic regression | Willingness to consider JR was assessed by interview with patient, using the question, “If your pain were to get severe, would you consider surgery to replace your knee/hip if your doctor recommended it?” yes/no | Age, median annual household income, educational level, GDS score, disease severity per WOMAC, and Kellgren/Lawrence (K/L) score = radiographic evaluation scale. Further analyses also adjusted for familiarity with JR and outcome expectations. | 596 elderly males with moderate-to-severe symptomatic knee or hip OA 262 blacks 334 whites | Outcome: response to question of whether patient would consider hip or knee replacement surgery if their pain were to become more severe and the doctor recommended it. Blacks were more likely to respond no, adjusted for age, median income, education, GDS score, disease severity (WOMAC score), and K/L score: OR 0.54 (0.30–0.96) Adding adjustment for familiarity with joint replacement (see Ibrahim, 2002 #1697), the difference remained significant: 0.53 (0.30–0.96). Adding adjustment for expectation of outcomes and familiarity, there was no longer a difference: 0.86 (0.45–1.63). This suggests that differential expectations of postsurgical hospital course, pain, and function mediated the observed difference in “willingness”. | A study of Medicare claims data by Katz (ref 27) suggested that blacks perceived perhaps accurately a higher risk of complications from JR therapy. The study found that blacks were more likely to receive JR in low-volume hospitals where the risks of complications or poor outcomes were higher. Ibrahim posits that the results of the current study hint at a possible mechanism for Katz's finding: blacks may be more likely to be exposed to anecdotal knowledge of complications of JR surgery and as a result would be less “willing” than whites to consider JR even when recommended. Differential expectations of postsurgical hospital course, pain, and function mediate the observed differences in “willingness” in this study.
Ibrahim, 2002 | Understanding ethnic differences in the utilization of joint replacement for osteoarthritis: the role of patient-level factors | To examine how black and white potential candidates for joint replacement (JR) compare with respect to their overall familiarity with joint replacement as an option, as well as their perceptions of the risks/benefits of this procedure. | cross-sectional survey | 596 | Cleveland VAMC | Black v. white | See Ang, 2002, Ibrahim 2002 #1696, Ang 2003 Participants in the VA-funded study on Ethnic/Cultural Variations in the Management of Osteoarthritis, 1997–2000. From the list of patients scheduled for primary care visits, study staff approached potential participants as they entered the waiting room to be seen. Patients were screened using questions on presence, duration, and severity of hip or knee pain. eligible patients were 50+ and had moderate to severe pain (per Lequesne Scale) for >6 months. Excluded those who already had knee/hip replacement. | Self-report via interview. | Familiarity with joint replacement therapy for OA (Qs 1–3) Perceptions of risk and benefits (Qs 4–7) | Multivariate logistic regression | Interviewers asked participants the following questions during a primary care visit: 1) have you ever heard of surgery to replace a hip or knee that has been damaged by arthritis 2) Do you have family or friends that have had a hip or knee replaced by surgery 3) Do you have a good understanding of what happens to somebody when they undergo hip or knee RS? 4) how often do you think someone dies as a result of hip or knee RS 5) How long do you think someone who has hip or knee RS would be in the hospital? 6) Sometimes people who have extreme pain in their hip or knee choose to have joint RS. How much pain do you think people will still have after they have recovered from their surgery? 7) Sometimes people who have extreme difficulty walking choose to have JRS. How much difficulty walking do you think people will still have after they have recovered from their surgery? | Age, educational level, annual household income, Charlson comorbidity index, WOMAC score, and Geriatric Depression score | elderly males with symptomatic knee or hip osteoarthritis 262 black 334 white | Bivariate findings, compared with whites: Blacks were less likely to have ever heard of JR though not to significance (81% v 87%, p=0.065), to have had family or friends who had had JR (52% v 78%, p<0.001), or to report a good understanding of JR as a form of treatment (44% v 61%), p<0.001). Blacks were more likely to believe the hospital course after surgery could last >2 wks (45% v 18%, p<0.001) and that the recovery period would last >6 months (47% v 40%, p=0.086). Blacks were more likely to expect moderate or extreme pain (62% v 42%, p<0.001) and moderate to extreme difficulty walking (64% v 39%, p<0.001) following JR. Adjusted OR (95%CI), black v. white (referent) Significant items on familiarity with joint replacement surgery: Ever hear of JR: 0.64 (0.97–1.09) Family/friends had JR: 0.39 (0.26–0.61) Good understanding of JR: 0.62 (0.42–0.92) Significant items on perceptions of risks & benefits: Hospital course greater than two weeks: 4.09 (2.57–6.54) Moderate to severe pain after JR surgery: 2.61 (1.74–3.89) Moderate to severe difficulty walking after JR surgery: 2.76 (1.83–4.16) | Blacks were much less likely than whites to have a friend or relative who had JR surgery for OA, and were less likely to report a good understanding of the treatment. Blacks were significantly more likely to expect a longer hospital course and express concerns about postsurgical pain and difficulty walking. These differences were not explained by clinical disease status, age, or differences in SES. Author suggests that if it is proven that patient-level factors such as familiarity with the procedure play a role in explaining disparities in utilization, it is possible to intervene through patient-targeted education.
Ibrahim, 2003 | Older patients' perceptions of quality of chronic knee or hip pain: differences by ethnicity and relationship to clinical variables | To examine whether patient descriptions of chronic pain vary by ethnicity and if they correlate with important clinical measures used in arthritis care. | cross-sectional survey | 300 | VA outpatient clinics, NOS | Black v. white | Potential participants were identified from the log of patients scheduled for primary care visits at VA outpatient clinics. Eligible patients were aged 50+ with moderate to severe pain for more than 6 months (per Lequesne scale). Excluded patients who already had knee or hip replacement. | Self-report via interview. | Quality of pain - assessed by asking, “Here are some words that patients like yourself sometimes use to describe their pain. Please tell us how applicable they are for your pain.” descriptors: sharp, dull, hot, achy, stabbing, stiff, sore, tender, throbbing, and frozen. Frequency: never, sometimes, always. WOMAC; Radiologic evaluation using K/L scoring; Quality of life measure; Visual analog scale (VAS) of pain; Geratric Depression scale; Charlson comorbidity index | Factor analysis with varimax rotation. Pearson correlations were used to assess relationship btw eqch quality of pain factor and WOMAC, K/L grade, VAS for pain, and global QOL ratings. Whites and Blacks analyzed separately. | Self-report by interview. | None | 300 male veterans aged 50+ with moderate to severe symptomatic knee or hip osteoarhritis. 45% black (n=135) 55% white (n=165) | Quality of pain descriptions did not correlate with radiologic stage of disease (K/L) in either race group. There was modest correlation between quality of pain factors and WOMAC scores for both blacks and whites. Although global QOL rating correlated negatively with some of the quality of pain factors for whites, there were no correlations between any quality of pain factors and the global QOL rating for blacks. | Author concludes: Elderly blacks and whites with chronic knee or hip OA describe the quality of their pain differently. The relationship between quality of pain and global QOL ratings also varies between whites and blacks. Patient descriptions of quality of chronic knee or hip pain do not correlate with radiologic stage of disease.
Jones, 2005 | Racial disparity in knee arthroplasty utilization in the veterans health administration | To conduct an analysis of the VA National Patient Care Database (NPCD) to examine total knee arthroplasty (TKA) utilization in a national sample of patients aged 50+ who have been diagnosed with OA. | Retrospective cohort study | 260,856 | National patient database | Black v. white | Included all VA outpatients during FY 1999 aged 50+ and had a diagnosis of OA code 7.15.x. Also identified a subset of patients who had been referred to rheumatology or orthopedic clinics for specialty care, to narrow the population to be more likely to be candidates for TKA. Excluded Hispanics from analysis. | PTF and OPC | TKA within a 2-year followup period (2000–2001) after receiving an OA diagnosis in 1999. | Multivariate logistic regression | Data on comorbidity were collecting using components of the Deyo-Modified Charlson Index. | age, sex, Charlson comorbidity index | Mostly males (96–98%) 1) OA general cohort: 85.7% white (n=223,604) 14.3% black (n=37,252) N missing race data or race not NonHispanic white or black=68,605 2) Specialty clinic subcohort: 85.5% white (n=39,488) 14.5% black (n=6719) | Blacks were significantly less likely than whites to have received TKA within 2 years: OA cohort: adjusted OR 0.72, 95%CI 0.65–0.80 Subcohort: adjusted OR 0.72, 95%CI 0.63–0.81 The model adjusted for age, sex, and comorbidity. | Blacks were significantly less likely to undergo the procedure compared with whites. Authors suggest further study to examine patient-level or provider-level factors that explain this disparity.
Lopez, 2005 | Patient perceptions of access to care and referrals to specialists: a comparison of African-American and white older patients with knee and hip osteoarthritis | To examine whether patients' perceptions regarding healthcare access; satisfaction with care; and other non-patient factors, such as referrals to specialist care (orthopedics and rheumatology), vary by race/ethnicity. | See Ang 2002; Ang 2003; Ibrahim 2002 | 596 | Cleveland VAMC | black v. white | Patients aged 50+ were approached during routine primary care clinic visits at the Louis Stokes Cleveland VAMC btw 1997–2000. Excluded pts who already had knee and hip replacement. | Self-report, by interviewer- administered questionnaire | Patient confidence and satisfaction with knee and hip pain care was assessed by 5 Qs; Patient perceptions regarding access to care, 2 Qs; Additional non-VA insurance; Receipt of referrals for specialist care (rheumatology & orthopedics) | Logistic regression models | Patients’ responses were gathered by interview. | Age, income, educational level, K/L scale (radiographic stage of disease); Charlson comorbidity Index; WOMAC to assess lower-extremity pain and function in OA | See Ang 2002; Ang 2003; Ibrahim 2002 | Bivariate analyses, confidence in & satisfaction with care: Blacks were less likely to consider the patient-physician relationship as excellent (24.7% v 36.3%, p<0.01). Blacks were less likely to express confidence in their primary physicians (75.7% v 82.6%, p=0.04) In multivariate analysis, quality of relationship with and confidence in primary physician were similar between blacks and whites. Access to care: significantly more whites than blacks reported that it was difficult to get medical care when they needed it (27.9% v 19.5%, p=0.02). This difference persisted in multivariate analysis: adjusted OR for difficulty getting medical care, black v. white(referent)= 0.54, 95% CI 0.34–0.88 (p=0.01). Perceived difficulty in accessing care outside the VA was similar btw groups (52.4% v 52.2%, p=0.95). Additional non-VA insurance: Significantly more blacks reported not having any additional nonVA insurance (44.5% v 28.6%, p<0.01), including Medicare, Medigap, and private or group insurance. These differences persisted in multivariate analyses. Referrals: There were no sig. racial differences in the proportions who received referrals for specialist care, although a greater proportion of whites recevied referrals to orthopedic clini (24.2% v 17.4%, p=0.06). Multivariate analyses: there was a tendency favoring white patients with regard to referral to orthopedics for similar indications (adjusted OR 0.61, (0.36–1.03, p=0.07). | Blacks reported having only VA insurance more often than whites. Other aspects of perceived system and provider-based factors were similar between blacks and whites.
Selim, 2001 | Racial differences in the use of lumbar spine radiographs: results from the Veterans Health Study | To determine whether clinical differences and/or race account for disparities between white and nonwhite patients in the use of lumbar spine radiographs. We used comprehensive case-mix adjustment to address this question. | Prospective observational study of pts. using ambulatory care | 342 | Part of the Veterans Health Study | Nonwhite v. white | Patients with low back pain (LBP) were identified by self- report using 3 questions (ever had LBP, have LBP that began more than 3 months ago; had a health care provider visit for LBP in the past year). A positive response to all 3 questions signified clinically important LBP. 401 returned for followup. Excluded 6 patients with missing info about radiograph use; 53 excluded because of a prior use of MRI or CT scan. Excluded 25 patients with prior radiographs who reported having had an MRI or CT scan during the 12 month followup, to limit the study to patients who have had repeat plain films. Also excluded 28 subjects with an MRI or CT scan of the spine without having had a lumbar spine film. | self-report | At baseline and 12-month followup; Pts were mailed the Medical Outcome Study Short Form health Survey (SF-36). They were also scheduled for an in-person interview in which they completed an LBP questionnaire, a comorbidity index (CI), and a straight leg raising (SLR) test. The LBP questionnaire included radiating leg pain and the intensity of localized LBP (adapted from a validated scale for pain intensity, measured as sum of four items from 0=no pain, to 100= worst pain score. | Multivariate logistic regression | Self-administered questionnaire: roentgenography use was ascertained at baseline by asking “have you hadd plain radiographs, also called lumbosacral spine films, taken for low back pain? And at followup by asking “in the last 12 months, have you had plain radiographs…” | age, education, income, comorbidities, LBp intensity, radiating leg pain, SLR, physical component summary (PCS) and mental component summary (MCS) of SF-36. | Nonwhite (n=27): 22 black, 4 nonwhite Hispanic, 1 other race White (n=315) | Among 2425 participants in the VHS, 572 had LBP at baseline (prevalence 23.7%). Nonresponders were examined for sociodemographics and baseline functional status scores. 12-month followup rate was 70%. In unadjusted bivariate analyses, nonwhites had lumbar spine films more often than white patients (48% v 27%, p=0.024) Nonwhites and whites were similar in the number of physical and mental comorbidities. Nonwhites had higher pain intensity scores and more radiating leg pain than whites. Nonwhites had worse physical functioning, general health perception, social functioning, and role limitations due to emotional problems. With adjustment for confounders, only having a positive SLR test (positive = causes pain, numbness, or tingling radiating below the knee when leg was at or below 60 degrees of elevation) and lower MCS scores (indicating poorer mental health) remained independent predictors. Race was no longer significant after adjusting for age, education, income, comorbidities, LBP intensity, radiating leg pain, SLR, physical component summary (PCS) and mental component summary (MCS) of SF-36. | Multivariate analysis revealed that the apparently greater use of lumbar spine radiographs in nonwhite patients was explained by the SLR test and mental health (MCS scale of the SF-36V). Whites and nonwhites in this study were comparable in education, income, and employment.
Tan, 2005 | Ethnicity, control appraisal, coping, and adjustment to chronic pain among black and white Americans | To identify similarities and differences among non- Hispanic black and white patients in pain appraisal, beliefs about pain, and ways of coping with pain. We also examined the association between these factors (appraisals, beliefs, coping) and patient perception or subjective experience of their functioning in each ethnic group. | Cross-sectional survey | 482 | DeBakey VAMC, Houston | Non-Hispanic black v. white | Included patients referred to the Integrated Pain Management Program (IPMP) of the Michael E. DeBakey VAMC, a tertiary teaching hospital in Houston, TX. 1265 self-report questionnaires were mailed to patients from 1995–1998; 564 were returned. This analysis included the questionnaire data of 128 non-Hispanic black and 354 non-Hispanic white patients who returned questionnaires. No significant differences were found in age, gender, ethnicity, marital status, or disability status between responders & nonresponders. | Self-report | Measures of control appraisals and pain-related beliefs: The Life Control scale of the West Haven-Yale Multidimensional Pain Inventory (WHYMPI) assess perceived control over pain, control over life, and ability to cope with problems and stressful situations Arthritis Self-Efficacy Scale - adapted by substituting “chronic pain” for “arthritis” resulting in a Pain Self-Efficacy Scale with 3 subscales: self- efficacy pain, self-efficacy function, and self-efficacy symptoms. Survey of Pain attitudes assess 7 beliefs: control over pain, disability, harm, emotion (belief that emotions influence pain), medication, solicitude (belief that others should respond solicitously to pain behaviors), and medical cure (belief that a medical cure exists for one’s pain). Measures of Coping: coping strategies questionnaire, Chronic pain coping inventory Measures of function & Adjustment: Center for epidemiological Studies- Depression Scale (CES-D); Roland-Morris Disability Questionnaire (RMDQ) | Factor analysis using Promax rotation; regression analyses | Self-administered questionnaires. | Demographic variables. In regression analyses, the criterion variables were Pain Severity, Depression, Disability, and Interference; Factor scores were predictors. | 128 black 354 white Pain sites varied as follows: 39% back pain (mostly LBP) 32% limb pain 19% neck/shoulder pain 6% headaches 4% “all over pain” 72% multiple sites | Five factors emerged: 1) Active coping; 2) Pain control and disability attitudes; 3) Behavioral coping; 4) External coping 5) Appraisal of emotion and solicitude Scores on Factors 2–5 were significantly different between blacks and whites. Blacks received lower scores on factor 2 and higher scores on factor 3, 4, and 5. These scores indicate that black patients were more likely to use behavioral coping strategies, and they reported lower levels of perceived control over pain and more disability and perceptions of harm due to pain than non-Hispanic whites. Blacks were also more likely to report using external pain-coping strategies such as praying/hoping. Blacks held a stronger belief than whites that others should be solicitous when they experience pain. | The results of the regression analyses indicated that ethnicity was not significantly associated with any of the measures of pain, depression, and functioning after controlling for the other demographic variables. The results also revealed that ethnicity did not interact with the factor scores to explain significant variance in pain severity, depression, disability, or interference. There were subsantial similarities between non-Hispanic black and white patients in their self-reported control appraisals of pain, coping with pain, and beliefs about pain. Blacks scored significantly higher only on 2 of the subscales: the Solicitude subscale - consistent with reports that the family and other sources of social support are important coping resources for many black individuals - and the Praying/Hoping subscale, consistent with previous research showing that black women are more likely than white women to report using praying/hoping as a pain-coping strategy for rheumatoid arthritis (ref 24).

EVIDENCE TABLE 2 VA-BASED STUDIES OF RACE AND QUALITY OF CARE FOR CANCER

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race/ethnic groups compared | Source of race data | Type of outcome: describe | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Characteristics of study pop | Results, describe qualitatively | Comments
Akerley, 1993 | Racial comparison of outcomes of male Department of Veterans Affairs patients with lung and colon cancer | To distinguish between genetic vs socioeconomic factors or artifacts inherent in retrospective studies to discover explanations for the apparent shorter survival of blacks than whites with lung and colon cancer. | Prospective cohort study; cross-sectional assessment of Tx Hx | 704 | 12 VAMCs | All patients with SCC or NSCLC staged as either advanced locally or disseminated, or disseminated colon cancer, who had not previously received chemotherapy were recruited at 12 VAMCs into a DBRC trial of placebo v. RA-233 (VA Cooperative Study 188, conducted 1981–1986). This analysis includes data on black and white men only. | Black v. white | NR | Time to tumor progression, tumor response, and survival time. Patients received the same standard chemotherapy regimen according to their disease category. Doses of chemotherapy and experimental therapy administered were recorded at each follow- up visit. | NR | Bivariate analyses | None | Men with lung or colon cancer 100% male Mean age 60 18% black 82% white | At baseline, fewer blacks than whites had prior tumor resection (20% v. 29%, p<0.05) and prior radiation therapy (24% v. 32%, p<0.10). During the study, blacks and whites were comparable in intensity of treatment: median dose of chemotherapy given at each clinic visit did not differ between race groups. | Primary outcomes not relevant (time to tumor progression, tumor response, and survival). More detail on methods in refs. 13, 14.
Dominitz, 1998 | Race, treatment, and survival among colorectal carcinoma patients in an equal- access medical system | To assess the influence of race on the treatment and survival of patients with colorectal carcinoma | retrospective cohort study | 3176 | National VA database | All white or black male veterans given a new diagnosis of colorectal carcinoma in 1989 at VAMCs nationwide. | Black v. white | Administrative records: PTF and OPC | Likelihood of surgical resection, chemotherapy, radiation therapy, and death | PTF - patient treatment files and OPC - outpatient clinic files | Multiple logistic regression | age, region, marital status, comorbidity, VA eligibility status (service-connected, nonservice- connected, or other), distant metastases, and tumor location | Men with colorectal carcinoma 82% white 17.9% black | Adjusted OR (95%CI) of each treatment and mortality, comparing blacks to whites (1.00, reference) Surgical resection: 70% v. 73%, OR 0.92 (0.74–1.15) Radiation therapy: 17% v. 16%, OR 1.10 (0.85–1.43) Chemotherapy: 23% v 23%, OR 0.99 (0.78–1.24) Mortality: 42% v 39% 5-year survival; OR 1.13 (1.01–1.28) | Author’s comments: race was not associated with the use of surgery, chemotherapy, or radiation therapy in the treatment of colorectal carcinoma. Mortality from all causes was higher among blacks with colorectal carcinoma, but this finding may be attributed to underlying racial differences associated with survival.
Dominitz, 2002 | Race, treatment, and survival of veterans with cancer of the distal esophagus and gastric cardia | To assess the influence of race on the treatment and survival of patients with distal esophageal cancer | retrospective cohort study | 1521 | National VA database | PTF records of VA hospitalizations for 1993–1997 were used to identify all veterans discharged with a diagnosis of distal esophageal cancer. Analysis was limited to males whose race was coded as white or black. | Black v. white | Administrative records: PTF | Utilization of surgical resection, chemotherapy, and radiation therapy; survival. Treatment was determined for all patients for 6 months before the index hospitalization and for at least 1 year following the index hospitalization. | PTF - patient treatment files and OPC - outpatient clinic files | Multiple logistic regression | Age, marital status, comorbidity, VA eligibility status, and presence or absence of metastasis | Men with distal esophageal cancer 100% male 15.2% black (n=231) 84.8% white (n=1290) Adenocarcinoma: n=78 blacks n=548 whites Squamous cell carcinoma: n=161 blacks n=734 whites | At baseline, blacks with squamous cell carcinoma (SCC) were less likely than whites to have a CT scan: 37% v. 53%, p=0.0003. This difference did not occur among patients with adenocarcinoma (49% whites v. 49% blacks had a CT scan). Unadjusted use of treatment, black vs white: Surgery 20.5% v. 35.3% Radiation 44.8% v. 36.0% Chemotherapy Adjusted OR (95%CI) for each treatment type among blacks with adenocarcinoma; SCC: Surgical resection 0.54 (0.30–0.96); 0.45 (0.29–0.70) Radiation therapy 0.99 (0.97–1.01); 1.72 (1.21–2.47) Chemotherapy 1.35 (0.80–2.29); 1.74 (1.19–2.54) Referent group; whites Blacks were significantly less likely to undergo surgery with either adenocarcinoma or SCC. There were no sig. racial differences in use of radiation and chemotherapy among pts with adenocarcinoma, but with SCC, radiation and chemo were used more frequently among blacks than whites. Blacks were more likely to receive combined chemo and radiation for SCC (OR 1.75, 95%CI 1.18–2.59, p=0.0005) but not for adenocarcinoma. | Blacks with SCC are less likely to have surgery but more likely to have radiation and chemotherapy. Blacks with adenocarcinoma are less likely to have surgery but equally likely to have radiation and chemotherapy. Explanatory mechanisms not studied.
Gordon, 2006 | Racial differences in doctors’ information-giving and patients’ participation | To determine whether doctor-patient communication differs by race in patients with pulmonary nodules or lung cancer. | Cross-sectional study | 137 | 1 large southern VAMC | Eligible patients had biopsy-confirmed lung cancer or a pulmonary nodule or mass requiring surgical diagnosis at presentation to thoracic surgery or oncology clinics at a large southern VAMC between 2001–2004. Pts with lung cancer were identified at diagnosis from pathology reports, and patients with suspicious pulmonary nodules were identified at a weekly multidiscipliary clinical conference. | Black v. white | Self-report | Doctor’s statements were coded by type and also by whether “self-initiated” or “prompted” by the patient’s communication. Patient’s participation was coded for 3 types of verbal behaviors: asking questions, being assertive, and expressing concerns. | Medical encounters were audio-recorded. Communication behaviors were coded using a validated system. | Multivariable mixed linear regression, treating physician as a random effect to adjust for patient clustering | Race, age, education, oncology clinic, mental health, physical health, companion present (triad/dyad), patient + companion participation | 96% male n=30 black n=107 white | Doctors’ self-initiated information-giving was not statistically different by race, after controlling for patient and visit characteristics, presence of a companion, and clustering of patients by doctor. When examining information-giving that was prompted by the patient, black patients received, on average, 16.5 fewer information- giving statements from their doctor, even after controlling for covariates. Patients (and companions) in racially concordant visits received significantly more info from their doctors (99.4 vs 62.1 mean utterances, p<0.001) and were significantly more active participants (41.7 vs 27.2 mean utterances, p<0.001) when compared with patients in racially discordant visits. After adjusting for patients’ active participation and other factors, doctors’ information-giving was not significantly different among racially concordant and discordant consultations (p=.37). In analyses stratified by whether information was prompted or self-initiated, doctors’ self-initiated information- giving was not sig. different by doctor-patient racial concordance after controling for patient and visit characteristics, the presence of a companion, and clustering of patients by doctor. When examining info-giving prompted by the patient, patients in racially concordant consultations received on average 18 5 more info-giving | Author concludes: black patients, and patients in racially discordant consultations, received less information overall because they less often engaged in communication behaviors (e.g. questions, concerns, assertions), that typically elicit more information from doctors. This suggests that disparities in medical care are related in part to the degree to which patients are actively involved. Author suggests: patient’s communication with their doctors can be improved with training to increase patient participation in medical encounters. note: study included 17 providers at 1 hospital
Gordon, 2006 | Racial differences in trust and lung cancer patients’ perceptions of physician communication | To examine whether racial differences in patient trust are associated with physician-patient communication about lung cancer treatment; to determine whether patients-perceptions of physician communication led to postvisit changes in trust contrasted with baseline or previsit level of trust in the physician and the health system when patients enter their consultations. | Pre-visit/post-visit cross-sectional study | 103 | 1 large southern VAMC | Patients with biopsy-confirmed lung cancer or a pulmonary nodule requiring surgical evaluation between 2001–2004. Patients were recruited upon presentation to the oncology or thoracic surgery clinic for evaluation and treatment recommendations. | Black v. white | Self-report | Pre-visit and post-visit trust in physician | Patients’ perceptions of their physicians’ communication were assessed by questionnaire with 3 scales (10-point, Likert-type e.g. strongly disagree/strongly agree): 1) physician informativeness in 5 items; 2) perception that physician values and respects them, ie supportive talk, in 5 items 3) physician’s involvement of patient in treatment decisions, ie partnership building, in 3 items. Additionally, 9 scale items from previously published trust scales: 5 of the items measured patient trust in physician, 4 in trust in VA health system. | Mixed-effects linear regression, treating physician as a random effect to adjust for patient clustering | Post visit trust in physician and in VA health system were adjusted for previsit trust, race, age, college, first visit, visit >20 minutes, oncologist, mental health, physical health, informativeness, partnership, supportiveness | 22% black 78% white | Black patients perceived their physician as less supportive, less partnering, and less informative than white patients. There were no differences by race in trust in the VA health system. Previsit trust did not differ between blacks and whites. Blacks had significantly lower postvisit trust in physician than white patients (mean score 8.0 v. 9.3, p=0.02), because white patients’ trust increased significantly after their visits while black patients’ trust remain unchanged: 8.2 v 8.0 for blacks, 8.3 v 9.3 for whites. All visits with black patients were racially discordant between patient and physician. | Author’s comments: with more extensive interactional skills training for physicians, improved communication during the clinical visit might be a means to promote greater trust in both physician and system. However, our findings also raise the question about whether there was variation in actual physician communication behaviors by race of patient, whether patients interpreted the communication behavior differently by race, or both.
Knight, 2004 | Ethnic variation in localized prostate cancer: a pilot study of preferences, optimism, and quality of life among black and white veterans | To prospectively evaluate preferences, optimism, involvement in care, and quality of life in black and white veterans newly diagnosed with localized prostate cancer; to examine differences in “change” within and between groups in perceived involvement in care, optimism, and QOL at 3 and 12 months post Dx | Prospective cohort study | 95 | 6 VAMCs in 5 states | Black and white veterans with localized prostate cancer from 6 VAMCs. All consecutive patients diagnosed in the 6 VA urology clinics were invited to participate. Patients were eligible if they had 1) histologically proven Dx of prostate adenocarcinoma; 2) no prior cancer diagnosis in the past 5 years (excl basal cell carcinoma of the skin); and 3) no prior treatment for prostate cancer. Patients were recruited after biopsy and before commencing treatment. This analysis excluded patients of ethnicities other than white or black. | Black v. white | Self-report | Patient preferences: used the time trade-off task and ranked 6 attributes in order of importance (appetite, bowel & bladder, energy and fatigue, mood, pain, and sex). Dispositional optimism: Life Orientation Test; Perceived Involement in Care Scale QOL: used the European Organisation for the Research and TReatment of Cancer-Quality of LIfe QUestionnaire | Face-to-face sessions with trained interviewers at clinic visit for demographic data, and utilites and importance rank tasks. Phone interviews for measures of optimism, perceived involvement in care, and QOL, conducted within 1 week of clinic visit, then at 3 and 12 months. Medical record: type of treatment received | 2-sample t-tests and Chi2 tests at baseline comparing race groups; Change scores btw 3 and 12 months and baseline for perceived involvement, optimism, and QOL. | None | Men with prostate cancer Mean age 68 among blacks, 69 among whites (p=ns) 41% black (n=31) 59% white (n=56) PSA>20 ng/mL 28% blacks, 12% whites (p=0.02) but Gleason scores were similar | Type of treatment did not differ between races, % black v. white: Surgery 29% v. 31% (p=ns) Radiation/hormonal therapy 42% v. 26% (p=0.20) Watchful waiting 29% v. 44% (p=ns) Optimism, perceived involvement in care, and QOL: there were no significant differences between races at baseline, and no sig. racial diffs in the magnitude of change in optimism and perceived involvement in care at 3 month and 12 months. A difference in perceived involvement in care emerged at 12 months, in that blacks decreased and whites increased their requests to clinicians for info about their Sx and medical care (p=0.05). There were few racial differences in QOL at baseline and over time. | Author’s comments: Blacks and whites had similar preferences except blacks saw mild health impairment as less desirable than did whites. Blacks and whites were similarly optimistic and involved in their medical care over the 1st year after diagnosis. There were few racial differences in QOL at baseline and over time. At 1 year, black men saw themselves as becoming less involved in their medical care than did whites, receiving less info about their condition and its treatment - similar to a previous study where blacks rated physicians as less participatory than did whites (ref. 48).
Margolis, 2003 | Racial differences pertaining to a belief about lung cancer surgery: results of a multicenter survey | To assess the origin, distribution, and importance of the belief that lung cancer spreads if exposed to air during surgery. | Cross-sectional study | 626 | 2 VA sites, 3 non-VA sites, 3 clinics serving pulmonary outpatients, and 2 clinics serving patients with lung cancer | Consecutive clinic attendees 1999–2000, using anonymous, self-administered questionnaires distributed by clinic personnel at the time of a clinic visit. | Black v. white | Self-report | Prevalence of study belief. Likelihood of being opposed to surgery because of belief. Likelihood of accepting physician’s advice that belief is false. | Self-administered questionnaire | Multivariate analysis | Race, sex, age, education, income, residence (urban/rural), region, Religion, clinic, site (VA v. non--VA) | 251 VA patients (40%) 151+127 + 97 non-VA patients 25% black 65% white 2% Asian 1% Hispanic 7% unknown/other | 61% of blacks v. 29% of whites thought that the study belief was true. (p<0.001) 19% of blacks v. 5% of whites cite the belief that exposure to air during surgery causes lung tumor spread as the basis for opposing lung cancer surgery. Compared with whites, blacks were significantly more likely to believe tumors spread when exposed to air, adjusted OR 3.50, 95%CI 1.89–6.49 (p=0.001). Blacks were significantly more opposed to surgery because of this belief, adjusted OR 5.35, 95%CI 1.66–17.3 (p=0.005). Blacks were significantly less likely to accept physician’s advice that this belief is false, adjusted OR: 0.21, 95%CI 0.07–0.64 (p=0.006). The analysis adjusts for VA vs non-VA clinic site. The ORs (95%CIs) were not significantly different between VA and non-VA sites on any of the 3 key survey questions. | Results combine VA + non-VA populations, but adjusts for VA v. non- VA site in the multivariate analysis. There were no sig. differences between clinic sites in the 3 key outcomes.
Street, 2006 | The clinical context and patient participation in post-diagnostic consultations | To examine the way patients communicate with physicians in two diverse post-diagnostic settings, post-angiogram consultations and initial lung cancer visits. | Cross-sectional study ofphysician-patient interactions | 88 heart 62 lung | 1 VAMC, same study as Street 2005 | VA sample made up of patients with lung cancer at a Texas VA hospital. Data came from a study to evaluate whether physician-patient communication was associated with patient’s ethnicity, trust in doctor, and satisfaction with care. Patients in the study had a diagnosis of lung cancer or a pulmonary nodule that was suspicious for lung cancer. From 130 audiotaped visits of the patient’s first visit to that physician, excluded 65 visits in which a companion was present and contributed >15% of total patient plus companion talk, leaving 65 interactions in this study. | Black v. white | Self-report | 3 measures of patient participation: N of active participation behaviors, proportion of patients’ utterances in the form of active participation, and conversational involvement (ratio of patient utterances to physician plus patient utterances). | 3 measures of patient participation were coded from transcripts and audiogrecordings of post-angiogram consultations and initla lung cancer visits: | Mixed linear regression | Clinical setting (lung cancer vs post-angiogram), physicians’ facilitative communication (partnership-building and supportive talk), and patients’ age, education | 62 patients with lung cancer (45 whites, 17 blacks), 88 patients post-angiogram (64 whites, 24 blacks) 27% black 73% white | Black patients were less active communicators than were white patients. Adjusted means (95%CI) for total active patient participation among whites was 18.25 (12.62–23.86) and among blacks, 11.04 (4.62–17.45), p=0.005. Clinical setting was a significant predictor of total active patient participation. Patients were more active participants in the lung cancer setting than post- angiogram. Adjusted means (95%CI) for total active patient participation was 27.50 (20.56–34.45) for lung cancer, and 1.78 (−6.53–10.09), p<0.001 for post-angiogram. This analysis was adjusted for ethnicity, patient education, patient age, and physician facilitation. | Authors suggest “patient activation” interventions to promote the legitimacy of the patient’s involvement in care, provide information about the patient’s health condition and treatment options, and offer specific communicative strategies (eg, writing down questions and concerns before the visit) for their interactions with physicians. Moreover, patient activation interventions can be conveniently and successfully delivered just before the consultation when there is an immediate opportunity to act on the motivation and skills gained from the intervention.

EVIDENCE TABLE 3 VA-BASED STUDIES OF RACE AND QUALITY OF CARE FOR CARDIOVASCULAR DISEASE

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race/ethnic groups compared | Source of race data | Type of outcome: describe | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Characteristics of study pop | Results, describe qualitatively | | | | | Comments
Bosworth, 2004 | Patient risk perceptions for carotid endarterectomy: which patients are strongly averse to surgery? | To examine factors that would explain patient aversion to carotid endarterectomy (CEA), using a single item that asked patients to what degree they agree with the statement that it is best to say no to surgery no matter what. | Cross-sectional survey | 1065; 1001 in final model | 5 VAMCs | Black or white patients were eligible if they had undergone carotid ultrasound or Doppler scanning btw 1997–1999 and had not previously undergone CEA. For every two white patients with > 50% stenosis enrolled, the next subject with <50% served as a control. For black patients, every patient with >50% stenosis and enrolled, the next black subject with <50% served as a control. Excluded patients with poor mental status, race other than black or white. 4% eligible refused to participate. | Black v. white | Self-report | Patient agreement to a single item: “To what degree do you agree with the statement, “It is best to say no to surgery no matter what.” Response categories combined “strongly agree, agree, do not know” and compared with “disagree” and “strongly disagree”. | Medical record review; psychosocial factors were gathered using the Multidimensional Health Locus of Control scale, Physical and mental health sub-domains of the Medical Outcomes Study SF-12, the Trust in Physician scale, and the Abbreviated Interpersonal Social Evaluation List for social support. | Multiple logistic regression | Variables entered in backward elimination model included demographic (age, race, medical center site, education, and living alone) and clinical factors (prior surgical experience, operative risk, neurologic status, comorbid conditions) and psychosocial factors (multidimensional health locus of control, health- related quality of life, trust in physician, social support). | Patients who underwent carotid ultrasound scanning | Adjusted OR (95%CI) for risk aversion, blacks v. whites (referent) = 1.78 (1.11–2.86) Final model adjusted for no previous surgery as an adult, chance locus of control, internal locus of control, trust in physician, and social support score, site, living alone, and mental health component score. Baseline neurologic status, education, myocardial infarction, and operative risk for CEA were removed from the model due to non-significance. In addition to race in the multivariate model, increased age, no previous surgery, lower level of chance locus of control, less trust of physicians, and less social support were significantly related to greater likelihood of surgery aversion among individuals referred for CEA evaluation. | | | | | Authors suggest that interventions designed to assist patient decision making should focus on multiple factors related to CEA aversion.
Charles, 2003 | Racial differences in adherence to cardiac medications | To determine whether there are racial differences in adherence to cardiac medications | Retrospectve cohort study | 5269 | VA Pittsburgh Healthcare System (VAPHCS) | Black and white veterans aged 45+ who had at least 3 refills for one of the study drugs during an 18-month period in 1996–1998. Subjects received any of four groups of drugs: Angiotensin-converting enzyme inhibitors (ACEIs), beta-blockers (BBs), calcium channel blockers (CCBs) or hydroxymethyl glutaryl coenzyme A (HMG CoA) reductase inhibitors (statins). Outpatient and inpatient records were analyzed during 1995–1997 to determine comorbidity. | Black v. white | Administrative records | Adherence ratio (AR) = cumulative days of pills supplied/cumulative days elapsed from the first refill to the last refill of the medication. Dichotomous adherence was defined as adherent = having an AR >80% | Admin data: outpatient and inpatient visits, computerized pharmacy records | Multivariate logistic regression | Age, medical comorbidity, and complexity of the medication regimen, and a race*age interaction term. | Veterans with prescriptions for cardiac medications 833 blacks 4436 whites | In unadjusted analyses, among BB users, blacks and whites were equally adherent (84.8% blacks, 83.5% whites, p=n2). Blacks were less likely than whites to be adherent to ACEIs (81.4% v 87.6%, p=0.004), CCBs (75.3% v 81.7%, p=0.003), and statins (59.9% v 74.1%, p<0.001). In analyses stratified by age, among users of ACEI users, blacks aged 74+ were significantly less adherent than whites in the same age group (OR 0.40, 95%CI 0.22–0.73) but there were no significant racial differences in younger age groups with ACEIs. Blacks were less adherent than whites among younger ages among users of CCBs: age <55 OR 0.55 95%CI 0.32–0.94; age 55–64, OR 0.55 95%CI 0.34–0.91, as well as statins: age <55 OR 0.43, 95%CI 0.22–0.82. There were no racial differences stratified by age among users of BBs. Results of multivariate analyses were not reported, except the statement that the relationship among race, age, and compliance was unchanged controlling for comorbidity and complexity of the medication regimen. | | | | | Authors conclude that racial differences in adherence to medications were found primarily among veterans younger than 55 years old. These differences were most prominent among younger African Americans taking CCBs or statins. Of note: with ACEIs, the oldest age group showed less adherence among blacks, and no differences were found at younger ages.
Collins, 2002 | Racial differences in how patients perceive physician communication regarding cardiac testing | To assess racial differences in attitudes about the physician-patient relationship and cardiac testing; to investigate patients’ perceptions of their interaction with providers regarding cardiac testing. | Qualitative study of focus group sessions | 13 | Houston VAMC | Administrative data was used to identify patients who had undergone cardiac stress tests with positive findings in the previous 12 months. Patients were sent introductory letters and follow-up phone calls for recruitment. 21 agreed to participate, 8 showed up for the focus groups, 90 minutes each. Group 1: black patients having only undergone a stress test Group 2: white patients having only undergone a stress test Group 3: white patients having only undergone a stress test together with those having undergone an invasive cardiac procedure after a stress test Group 4: black patients having only undergone a stress test together with those having undergone an invasive cardiac procedure after a stress test. | Black v. white | Not specified | In focus groups, patients were queried regarding their experiences surround care received at the VA for heart disease including hospitalizations, stress tests, invasive procedures, and surgery; also asked about their perceptions about their health, the physicians treating them, and the treatment decision-making process. | Focus groups. Transcripts were coded for emergent categories. | Analysis focused on problems in patient- physician communication about sharing results of diagnostic tests and making decisions for procedures. | None | patients with positive cardiac stress tests, aged 47–85 6 blacks 7 whites | Four themes emerged regarding problematic characteristics of communication with providers: 1) The substance of the information communicated. Information from providers could be vague, unclear, confusing to patients 2) Patients’ perceptions of present recommendations in light of their prior experience and expectations 3) Patients’ expressed requirement to be convinced of the need for an invasive procedure prior to agreeing to pursue one 4) Patients’ desires for the establishment of a relationship of trust with the physician The themes did not apply equally across the racial groups: White patients asserted but no black patients indicated the need to be convinced about the need for a procedure. Whites considered the possibility of further testing with skepticism. Black patients expressed the need for trust in physician but there was no evidence that whites expressed the same need to trust their physician before undergoing procedures. Patients of both races disclosed a lack of clarity, difficulty in understanding, and uncertainty surround the communication with their physicians regarding cardiac testing. with skepticism. Black patients expressed the need for trust in physician but there was no evidence that whites expressed the same need to trust their physician before undergoing procedures. Patients of both races disclosed a lack of clarity, difficulty in understanding, and uncertainty surround the communication with their physicians regarding cardiac testing. | | | | | Patients expressed concern about poor communication with their physicians. A theme expressed by black patients was the desire to build a relationship with a physician before making a decision on an invasive procedure. White patients expressed a desire for receiving information before agreeing to an invasive procedure, without the need of knowing the physician.
Collins, 2002 | Lower extremity nontraumatic amputation among veterans with peripheral arterial disease: is race an independent factor? | to determine if race/ethnicity is independently associated with an increased risk for nontraumatic lower extremity amputation versus lower extremity bypass revascularization among patients with peripheral arterial disease (PAD). | Prospective cohort study | 11494 | NSQIP Phase I and II. | National Surgical Quality Improvement Program (NSQIP) Phase I included 44 academically affiliated VAMCs that performed cardiac and noncardiac surgery between 1991–1993; Phase II included an additional 79 VAMCS that performed major surgery between 1994–1995. Eligible patients were aged 18+ and nderwent a lower extremity amputation or lower extremity bypass revascularization for arterial occlusive disease involving the abdominal aorta and/or the lower extremity within eitheri Phase I or Phase II. | Non-Hispanic white, black, or Hispanic | PTF | Lower extremity amputation versus lower extremity bypass revascularization | PTF; NSQIP data | Multiple logistic regression, stepwise | Variables considered in the model (but weren’t all kept): diabetes mellitus, hypertension, MI, CHF, COPD, TIA, CVA, impaired sensorium, weight loss, functional status, ASA-class, smoking, ethanol use, emergency operation. | Patients with PAD 416 Hispanics 2337 blacks 8741 non-Hispanic whites | Among patients who underwent a lower extremity amputation, 4.9% were Hispanic, 28.9% were black, and 66.2% were non-Hispanic white (p<0.01). Lower extremity revascularization: 79.7% white, 17.2% black, 3.1% Hispanic. Adjusted OR (95%CI) for lower extremity amputation vs. lower extremity revascularization, non-Hispanic whites as referent group: Blacks: 1.5 (1.4–1.7) Hispanics: 1.4 (1.1–1.9) | | | | | Race is an independent predictor of lower extremity amputation in patients with PAD. Other significant predictors of lower extremity amputation instead of lower extremity bypass revascularization were older age, poor functional status, congestive heart failure, recent weight loss, prior limb surgery, dialysis, and more severe PAD as captured by a history of rest pain or an open wound infection.
Conigliaro, 2000 | Understanding racial variation in the use of coronary revascularization procedures: the role of clinical factors | To determine whether racial differences in PTCA and CABG persisted after stratifying by clinical appropriateness of the procedure; to assess whether differences in clinical presentation, including comorbidity, operative risk, and coronary anatomy, explain the differences in the use of PTCA and CABG between black and white male patients admitted with AMI or unstable angina. | Retrospective cohort study | 666 | 6 VAMCs | Patients were selected from 6 VAMCs that had the capacity to perform CABG on site or at an adjacent university hospital. Patietns were identified using the PTF, selecting all black and white males aged 30+ who underwent a left heart catheterization during an admission for an acute MI or unstalbe angina, admitted between 1989–1995. Potential subjects were blocked by 5-year age, VAMC, primary diagnosis, and year of discharge; all black patients were selected in each blocks, and an equal N of white patients were randomly selected from that block. Patients were matched on age, admitting diagnosis, and medical center. Excluded patients who had had PTCA during the preceding year, any previous CABG, and those who developed ischemia while admitted for illness other than ischemic heart disease. | Black v. white | PTF | Use of PTCA and CABG with with respect to clinical appropriateness of the procedure; using criteria developed by RAND to rate procedures as “appropriate and necessary,” “appropriate but not necessary,” “inappropriate,” or “equivocal” based on clinical presentation, operative risk, and coronary anatomy. | Chart review; coronary anatomy (presence of coronary obstruction) was defined using the CC report. | Multivariate logistic regression | appropriateness, site of care, fiscal year, alcohol/drug/tobacco use, and presenting diagnosis | Males admitted for AMI or unstable angina 326 blacks 340 whites | Black patients were less likely than whites to undergo any revascularization procedure in the entire cohort (28% v 47%, p<0.001). Among the 539 patients with angiographically demonstrated coronary artery lesions, the racial difference persisted: 38% blacks vs 54% whites, p<0.001. Adjusted OR (95%) comparing blacks to whites (referent) for each procedure, includes 359 patients with appropriate indicators: Across all RAND indications (n=359): PTCA 0.86 (0.51–1.45); CABG 0.60 (0.35–1.06) By RAND indication: Only PTCA necessary (n=54): PTCA 0.34 (0.09–1.31); No blacks underwent CABG Only CABG necessary (n=166): PTCA 0.95 (0.29–3.10); 0.42 (0.20–0.86), p=0.03 Either necessary (n=59): PTCA 4.50 (0.91–22.29); CABG 2.26 (0.42–12.11) Neither necessary (n=80): PTCA 1.33 (0.44–4.03); CABG 0.67 (0.84–5.35) There was no difference in 1-year (5.2% v 7.4%) and 5-year (23.3% v 26.2%) mortaltiy between blacks and whites. | | | | | Among black and white male patients matched on age, race, admitting diagnosis, and medical center, blacks underwent CABG or PTCA less often than whites. Racial variation persisted for some indications with further adjustment for differences in comorbidity, severity of CAD, and operative risk using the RAND appropriateness criteria. It is unclear whether disparity in procedure use affects patient outcomes; no racial difference in 1- and 5-year mortality was observed. Authors recommend future research on patient preferences, physician-patient communication, and trust to address the physician-patient interactions that lead to a physician’s decision to offer revascularization and the patient’s decision to accept it.
Deswal, 2004 | Impact of race on health care utilization and outcomes in veterans with congestive heart failure | To determine racial differences in mortality in a national cohort of patients hospitalized with congestive heart failure (CHF) within the VHA, and to examine racial differences in patterns of healthcare utilization following hospitalization. | Retrospective cohort study | 21994 | National VA database | Included veterans hospitalized with CHF at 153 acute VA hospitals nationwide between 1997–1999. Included patients who had a first admission for CHF, defined as no VA hospitalizations for CHF in the 2 years prior. Excluded patients with missing race data, and race other than black and non-Hispanic white. | Black v. white | PTF, OPC | Short-term mortality: within 30 days of the date of the index admission. Intermediate-term mortality: at 1 and 2 years following discharge. Outpatient utilization: medical clinic visits and urgent care/emergency room visits. Inpatient utilization: all-cause readmission rate = average N of discharges per patient in the year following discharge. Bed-days of care rate = average N of days spent in the hospital for any admission per patient-year of followup after discharge. Medical readmission rate similarly calculated. | PF, OPC, VA death file | Hierarchical mixed models to calculate risk-adjusted rates of utilization per patient-year of follow-up, by race | Age, gender, income, marital status, and comorbidities. Patients were nested within hospitals and hospitals were nsted within Census Bureau divisions. | | Adjusted mortality OR (95%CI) at all time points was significantly lower in black patients than white patients: 30 day mortality: 0.7 (06–0.82) 1 year after discharge: 0.82 (0.75–0.9) 2 years after discharge: 0.84 (0.78–0.91) The survival advantage among blacks was consistent acorss subgroups of patients by age, presence of hypertension, presence of CAD, and presence of diabetes. Healthcare utilization: mean risk-adjusted rates per year of patient follow-up, black v. white: Outpatient visits to a principal medical clinic: 8.57 v 9.56 (ns) ER/urgent care visits: 2.00 v 1.61 (p<0.001) All-cause readmissions: 1.64 v 1.68 (ns) All-cause bed-days of care rates: 12.40 v 12.23 (ns) Rates of medical readmissions: 1.44 v 1.45 (ns) | | | | | After discharge, blacks on average received fewer medical outpatient clinics, and more ER/urgent care vistis. The readmission rates and bed days of care per patient-year of folllow-up were similar between blacks and whites. Author concludes: the racial gap in patterns of healthcare utilization is small. The observation of better survival in blacks after a CHF hospitalization is not readily explained by differences in healthcare utilization.
Deswal, 2006 | Racial variations in quality of care and outcomes in an ambulatory heart failure cohort. | To evaluate racial differences in QOC in a large national cohort of patients with HF treated within the abmulatory care setting of the VHA; to examine the impact of race on 1-year mortality | Retrospective cohort study | 18,611 | National VA database | Veterans with HFG treated in ambulatory clinics at VAMCs, sampled for the VA’s External Peer Review Program (EPRP) between 2000–2002. Excluded missing race and race other than black or white. | Black v. white | PTF, OPC | Quality of medical care based on EPRP data, including documentation of left ventricular ejection fraction (LVEF) and prescription of ACE inhibitors (ACEI) and B-blockers in patients with LVEF <40%. Also examined 1-year mortality, and 1-year all-cause and HF hospitalization. | PTF, OTC | Multivariate logistic regression | Age, sex, marital status, comorbidities, HF hospitalization in the prior 2 years, current smoking, LVEF, serum creatinine, sodium, hemoglobin level, systolic blood pressure, and medical center affiliation. | Patients with heart failure | Adjusted OR (95%CI) for each quality-of-care measure for HF, black v. white (referent): LVEF documentation: 1.29 (1.11–1.49) Patients with LVEF <40% on ACEI: 0.95 (0.79–1.13) Patients with LVEF <40% on ACEI or ARB: 1.06 (0.85–1.33) Patients with LVEF <40% on ACEI or ARB or nitrate-hydralazine: 1.11 (0.86–1.44) Patients with LVEF <40% on B-blockers: 0.92 (0.79–1.07) 1-year mortality did not differ significantly by race. Blacks were more likely to be hospitalized for any cause (adjusted OR 1.20, 95%CI 1.08–1.33) and especially for HF (adjusted OR 1.43, 95%CI 1.23–1.66). Although infrequent outpatient clinic use may contribute to more frequent hospitalization, blacks had a slightly higher number of visits to primary care clinics than whites (5.7 v 5.3, p<0.0001) as well as to cardiology clinics (1.7 v 1.3, p<0.0001). | | | | | LVEF was documented more frequently in blacks than whites: 89% v 82%, p<0.0001. In patients with LVEF <40%, the prescription of ACEI, ARB, B-blockers, or nitrate-hydralazine did not differ significantly by race. Quality of care assessed by select measures was similar to or better than that for whites. Mortality was similar by race, but blacks were more likely to be hospitalized, especially for HF. Authors suggest that identifying and targeting modifiable factors such as uncontrolled hypertension in blacks (higher prevalence observed in this study) may narrow the racial gap in hospitalizations.
Evangelista, 2002 | Racial differences in treatment-seeking delays among heart failure patients | 1) to describe racial differences in treatment-seeking delays for heart failure (HF) symptoms 2) to identify racial differences in hospital readmission rates, functional status, and total length of stay. | Retrospective cohot study | 753 | 1 VAMC | PTF: all patients discharged with primary diagnosis of HF between 1997–1998. Excluded if reason for admission was noncardiac. | Black v. white in multivariate analysis | Self-report, “determine d at entry into the VA system” | Treatment-seeking delay time defined as the amount of time between the patient’s awareness of symptoms and arrival at the hospital, ascertained using information provided by the admitting physician when patients presented to the hospital for worsening of HF symptoms. | PTF and chart review | Multiple linear regression, stepwise | Age, marital status, NYHA functional class for effect of race on delay times. | patients with heart failure 98% male, mean age 69 220 blacks 36 Hispanics 456 whites | Mean delay time was significantly longer (p=0.019) for blacks than other races: blacks = 3.2 days, whites = 2.8, Asians = 2.9, Hispanics = 2.8 In the multiple linear regression that adjusted for age, marital status and NYHA functional status, black race remained significantly associated with greater delay time in seeking treatment for HF symptoms (Standardized Beta 0.239, p<0.001). Blacks had significantly (p=0.001) higher hospital readmission mean rates (hospitalizations after index admission for HF symptoms within study period of 24 months): blacks = 1.8, whites = 1.5, Asians = 1.2, Hispanics = 1.3 Blacks had significantly (p=0.034) lower mean functional status (i.e. higher NYHA class): blacks = 2.0, whites = 1.8, Asians = 1.7, Hispanics =1.8. Total hospital length of stay did not significantly differ by race. | | | | | Blacks were more likely to delay seeking treatment and had higher hospital readmission rates and poorer functional status. Explanatory mechanisms were not examined. Author suggests providing culturally sensitive education for disadvantaged populations on early symptom recognition and to encourage patients to seek medical care promptly.
Ferguson, 1997 | Examination of racial differences in management of cardiovascular disease | To identify the clinical characteristics associated with, and to investigate the impact of cohort selection criteria on, interracial use of invasive cardiac procedures and to determine survival. | Retrospective cohort study | 1406 | Roudebush VAMC | Male inpatients aged 30+ discharged in 1993 with a primary diagnosis of CVD or chest pain. Excluded if ineligible for DVA care or received an invasive cardiac procedure within 90 days before index hospital admission, or race coded as other than African American or white. Index event was defined as the first hospital admission for one of the target conditions during the study period. | Black v. white | Administrative records | Invasive cardiac procedure use within prespecified periods after the index event: 60 days for CC and PTCA 90 days for CABG Survival by race | Electronic medical records: PTF and Roudebush VAMC medical record system; chart review to look for additional data such as patient refusal of recommended therapies. | Bivariate analyses of race with outcome | None | Men aged 30+ with CVD or chest pain. 211 blacks 1195 whites | Proportions; unadjusted OR (95%CI) for each procedure for total CVD cohort, for blacks with whites as referent group: CC 11% v. 25%; 0.37 (0.24–0.58) PTCA 2% v 4%; 0.60 (0.25–1.49) CABG 1% v 6%; 0.22 (0.08–0.63) Any 11% v 28%; 0.32 (0.21–0.50) Unadjusted survival rates; OR (95%CI) blacks v whites as referent: 30-day survival 95% v 96%; 0.75 (0.37–1.51) 1-year survival 84% v 88%; 0.63 (0.48–1.09) | | | | | Author concludes: invasive cardiac procedure use was significantly lower among blacks than whites, but these treatment differences did not lead to clinically significant differences in survival. Interraciail differences in cardiac procedure use may have been influenced by relevatn comorbiditiesa dn disease severity.
Ferguson, 1998 | Racial differences in cardiac catheterization use and appropriateness | To investigate the role of medical appropriateness as a potential explanatory factor in previously observed interracial cardiac procedure rate differences. | Retrospective cohort study | 200 | Roudebush VAMC | Eligible inpatients were identified in the inpatient admin database, PTF, discharged in 1993 with a primary discharge Dx of CVD or chest pain. Eligibility criteria were males aged 30+, including patients who died during index admission. Excluded if ineligible for VA care, if had undergone invasive cardiac procedure within 90 days prior to index admission, if race other than black or white, or if resided outside Indianapolis. A random sample of 100 patients per race was selected from a total of 470 eligible patients. Index event was defined as the 1st hospitalization for one of the target conditions during the study period. | Black v. white | PTF | Invasive cardiac procedure use within prespecified periods after the index event (60 days for CC and PTCA, 90 days for CABG) | PTF; chart review performed by a trained research nurse blinded to the study objectives, using a validated abstraction instrument (RAND). A study investigator blinded to patients’ race and cardiac procedure status recommended patients for procedure clinical indication categories and assigned appropriateness scores per RAND guidelines. | Underuse rate = (N c/Appropriate + s/procedure) divided by (N c/procedure c/Inappropriate score) | None | Males aged 30+ admitted for CVD or chest pain 100 blacks 100 whites | Bivariate analyses: Blacks underwent fewer CC than whites: 14% v 41% (p<0.01) Blacks were offered fewer CCs than whites: 20% v 42% (p<0.01) Procedure refusals were more frequent in blacks: 6 (30%) of 20 recommendations v. 1 (2%) of 42 recommendations (p<0.01). All refusals occurred among patients who received a rating of uncertain appropriateness for CC. Among patients who underwent CC, 1 (7%) of 14 blacks had a rating of inappropriate (overuse) compared with 4 (10%) of 41 whites. Among patients who did not undergo CC, 0 (0%) of 86 blacks had a rating of appropriate (underuse) compared with 2 (3%) of 59 whites. | | | | | Overuse of CC by blacks was 7%, by whites was 10%. Underuse of CC by 0%, and by whites was 3%. This study found no evidence of discriminatory underuse of CC among blacks. There was greater variability of cardiac procedure use among whites: 10% undergoing CC had an inappropriate score (i.e. overuse), while 3% not undergoing CC had an appropriate score (underuse). Author concludes that their previously observed interracial differences in invasive cardiac procedure use may be partly a function of overuse among whites rather than underuse among blacks. Blacks in this cohort had less severe cardiac disease presentations: only 6% had symptom severity that indicated CC as appropriate, while 62% were “inappropriate” for CC. Among whites, 20% were appropriate while 43% were inappropriate candidates for CC. See Conigliario 2000 on appropriateness. Blacks were more likely to refuse recommendations for invasive cardiac procedures than whites.
Goldstein, 2003 | Veterans Administration Acute Stroke (VASt) Study: lack of race/ethnic-based differences in utilization of stroke-related procedures or services | VASt (Acute Stroke Study) prospectively collected data from a cohort of patients hospitalized with acute ischemic stroke. In this study, VASt data were analyzed to determine whether there were race/ethnic differences in patients’ evaluations for ischemic stroke or its management. | | | 9-site prospective cohort study | 1073 patients with acute stroke hospitalized within the VHA between 1995–1997. Data on acute care practices were collected through medical record review with the use of a standardized chart abstraction protocol. Excluded patients whose stroke was iatrogenic, due to brain trauma or neoplasm, occurred during hospitalization for other medical conditions, was an extension of previous stroke, or occurred >7 days before admission. | Nonwhite v. white | Chart review | Use of diagnostic tests for stroke: brain CT, MRI, cerebral angiography, transthoraci and transesophageal echocardiography, 24-hr ECG, carotid ultrasound, carotid endarterectomy, and rehabilitation, speech, recreational, and occupationa therapy evaluations; DNR orders | chart review | Bivariate analyses: t tests and Chi-square tests | None | Men and women with acute ischemic stroke 520 whites 255 non-whites (88% black) | There were generally no significant race/ethnic-based differences in the utilization of a wide variety of diagnostic studies and treatments. Diagnostic tests, % white v. % nonwhite (p-value) Brain CT 91 v 92.2 (ns); Brain MRI 36.2 v 41.5 (ns); TTE 52.5 v 53.7 (ns) TEE 10.2 v 10.6 (ns); 24-h ECG 3.3 v 1.6 (ns) Carotid ultrasound 64 v 62 (ns); Cerebral angiography 8.5 v 3.1 (p=0.01) ECG 73.1 v 81.6 (p=0.01) Interventions, % white v. % nonwhite (p-value) tPA 0.6 v 0.4 (ns) Antiplatelet drug 93.2 v 92.1 (ns) Carotid endarterectomy 1.5 v 0.8 (ns) Rehabilitation evaluation 71 v 76.5 (ns) Physical therapy 70.5 v 74.9 (ns) Speech therapy 9.6 v 12.6 (ns) Occupational therapy 16 v 19.6 (ns) Recreational therapy 3.1 v 2 (ns) DNR order 11.9 v 11.4 (ns) | | | | | Results were similar when Hispanics were excluded from the analyses and whites were compared with blacks (data not reported).
Gordon, 2004 | Race and patient refusal of invasive cardiac procedures | To observe doctor-patient interactions to examine patients’ willingness to follow doctors’ recommendations. To determine the extent to which doctors recommended additional procedures after a stress test or angiogram, and whether patients indicated they would follow or not follow the recommendation and whether this patient preference varied by race and ethnicity. | Prospective cohort study | 681 | 1 VAMC | Patients were enrolled at 2 sites, 1999–2000 within a single VAMC: 1) patients presenting for an exercise treadmill test; 2) patients presenting for coronary angiography. | Black, Hispanic, v. white | Self-report | Medical interactions after an exercise treadmill stress test or after a coronary angiogram. Doctor recommendations for procedures (angiography after treadmill test; PTCA or CABG after angiography) were observed and noted. Patients were followed up for 6 months after the recommendation to determine procedure use. | Direct observation of doctor-patient verbal behavior; chart review | Bivariate analyses, Chi2 | None | Patients undergoing treadmill test or coronary angiography 23.5% black (n=160) 7.1% Hispanic (n=48) 69.5% white (n=473) | Proportions of patients recommended for angiography, PTCA, and surgery did not differ significantly by race. Among the treadmill patients there were no racial differences in doctor-level decisions against angiogram (13% (n=2) black or 0% Hispanic v. 8% (n=5) white, p=ns). 4 of 83 (4.8%) patients declined or did not return for recommended angiograms, and this was marginally more likely among black (13%, n=2) and Hispanic (33%, n=1) patients, compared with whites (2% n=1, p=0.05). No patients explicitly declined angioplasty. There was no statistically significant difference by race among patients who explicitly declined the angiogram: 8% (n=1) black or 33% (n=1) Hispanic v 0% white, p=0.06. In the cohort enrolled at the cath.lab, no patients refused a recommended angioplasty. There were no racial differences in doctor-level reasons for nonreceipt of recommended invasive cardiac procedures. % per Black, Hispanic, and White for each procedure received: Angiogram 79%, 67%, 90% (ns) Angioplasty 100%, 63%, 87% (ns) Surgery 50%, 67%, 78% (ns) | | | | | Author concludes: Patient refusals of recommended invasive cardiac procedures were infrequent and may explain only a small fraction of racial disparities in the use of invasive cardiac procedures. Author notes the Hawthorne effect - the insertion of an observer into clinical encounters might have changed patients’ decision-making behavior, leading to fewer refusals.
Gordon, 2005 | Physician-patient communication following invasive procedures: an analysis of post-angiogram consultations | 1) to describe phsyician-patient communication following coronary angiography, with particular attention to factors affecting physicians’ information-giving, physicians’ partnership-building (ie. Efforts to involve the patient in the consultation), and active forms of patient participation (ie asking questions, giving opinions, expressing concerns). 2) To determine whether physicians’ information-giving, partnership-building, and patient participation in post-angiography interactions varied depending on patient’s race. | Qualitative study of audio-recordings of post-angiogram consultations | 93 | 1 VAMC | 8 male cardiologist agreed to participate. Patients presenting to these cardiologists for scheduled catheterization were screened. Excluded patients who had previous revascularization, had cancelled catheterization, or were of race other than black or non-Hispanic white. Also excluded cases in which a research assistant was not available to attend the catheterization. Excluded consultations with inadequate or incomplete recordings. Excluded women and patients with missing info on education. | Black v. white | Self-report | Verbal behavior was coded using system by Street & colleagues Physician’s information-giving statements was coded in 2 categories whether self-initiated or prompted. Patient’s participation was coded for 3 types of behaviors: asking questions, being assertive, and expressing concerns. | Post-angiogram consultations took place in the catheterization lab or recovery area. The consultations were audiorecorded using a standard cassette recorder and a microphone near the patient’s head. | Compared frequency of total, prompted, and self-initiatied communication behaviors. Mixed effects regression analyses stratified according to whether the behaviors of interest were prompted or self-initiatied. | Age, education, phsyician training level, patient-clustering by physician | Men who underwent CC 18 blacks 75 whites | The mean frequency of physician’s total self-initiated information-giving utterances differed marginally by race, blacks v whites: 12.4 v 17.7, p=0.06. The mean frequency of physician’s self-initiated information-giving utterances was significantly lower in blacks: 9.8 v 16.6, p=0.003. The mean frequency of patient’s self-initiated utterances was significantly lower among blacks: 0.9 v 1.8, p=0.02. Total patient participation was marginally lower among blacks: 1.2 v 2.0, p=0.07. Author’s interpretation: Compared to their interactions with white patients, physicians generally self-initiated less information to black patients, but did provide more information in response to a patient’s question, assertiveness, or expression for concern. Black patients self-intiated these behaviors less often than did their white counterparts. Physicians therefore respond in a more positive way when black patients communicate their interests and needs. | | | | | Author’s conclusions: There was a tendency for physicians to self- initiate less information giving to black patients, and for black patients to self-initiate less active participation than white patients. These differences were attenuated when other variables (e.g. physician’s training level, disease severity) were adjusted for in the analysis, but the pattern suggests a potential cycle of passivity where blacks tend to receive fewer informational resources, and these patients in turn do less to prompt the doctor for more.
Groeneveld, 2007 | Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals | To determine if VAMCs with higher proportions of black inpatients performed fewer cardiac procedures or had larger racial differences in procedure rates than predominantly white VAMCs. | retrospective cohort study | 300614 | National VA database | Included only white or black veterans admitted to VA hospitals 1998–2003 in the US. Excluded if patient had no records with a valid race code or had conflicting race values in other records. Excluded if index hospitalization occurred before July 1, 1998 - therefore each included pt had not been admitted to a VA hospital for a similar indication for at least 6 months before the index encounter. Excluded patients with index encounters after Oct 2, 2003 to guarantee at least 90 days of followup data. Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI were determined based on patient demographics, clinical indications, and comorbidities. | Black v. white | hospitalization record or other VA hospital records. | 4 procedures were selected based on volume of use: bioprosthetic aortic valve replacement (AVR), ICD implantation, DCP implantation, and PCI (PCTA or stenting). | VA database of hospital admissions and outpatient care. Non-VA Medicare procedure use data from Va-Medicare merged files. | Multivariate logistic regression | site variables (whether VA hospital was an academic center and whether the hospital had >30% black inpatients); sex, age, diagnostic indicators for each technology, and comorbidities; interaction terms were tested. Non-VA procedure use via Medicare was examined in pats >65. | Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI 45029 blacks 255585 whites | Groeneveld, 2007 | | | | | For almost every hospital category and procedure, the adjusted OR for blacks receiving procedures compared to whites was <1. The magnitude of racial differences in cardovascular procedure rates was influenced by the academic affiliation and inpatient racial composition of VA hospitals. Hospitals with larger black populations do appear to have larger racial differences in procedure rates than predominantly white hospitals.
Groeneveld, 2007 | Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals | To determine if VAMCs with higher proportions of black inpatients performed fewer cardiac procedures or had larger racial differences in procedure rates than predominantly white VAMCs. | retrospective cohort study | 300614 | National VA database | | Black v. white | hospitalization record or other VA hospital records. | 4 procedures were selected based on volume of use: bioprosthetic aortic valve replacement (AVR), ICD implantation, DCP implantation, and PCI (PCTA or stenting). | VA database of hospital admissions and outpatient care. Non-VA Medicare procedure use data from Va-Medicare merged files. | Multivariate logistic regression | | Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI 45029 blacks 255585 whites | Adjusted OR for blacks receiving procedures comparing with whites, by VA hospital academic status and inpatient racial composition
Groeneveld, 2007 | Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals | To determine if VAMCs with higher proportions of black inpatients performed fewer cardiac procedures or had larger racial differences in procedure rates than predominantly white VAMCs. | retrospective cohort study | 300614 | National VA database | | Black v. white | hospitalization record or other VA hospital records. | 4 procedures were selected based on volume of use: bioprosthetic aortic valve replacement (AVR), ICD implantation, DCP implantation, and PCI (PCTA or stenting). | VA database of hospital admissions and outpatient care. Non-VA Medicare procedure use data from Va-Medicare merged files. | Multivariate logistic regression | | Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI 45029 blacks 255585 whites | Procedure | <30% black inpatients, academic hospital | <30% black inpatients, nonacademic hospital | >=30% black inpatients, academic hospital | >=30% black inpatients, nonacademic hospital
Groeneveld, 2007 | Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals | To determine if VAMCs with higher proportions of black inpatients performed fewer cardiac procedures or had larger racial differences in procedure rates than predominantly white VAMCs. | retrospective cohort study | 300614 | National VA database | | Black v. white | hospitalization record or other VA hospital records. | 4 procedures were selected based on volume of use: bioprosthetic aortic valve replacement (AVR), ICD implantation, DCP implantation, and PCI (PCTA or stenting). | VA database of hospital admissions and outpatient care. Non-VA Medicare procedure use data from Va-Medicare merged files. | Multivariate logistic regression | | Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI 45029 blacks 255585 whites | AVR | ns | ns | 0.45, p<0.001 | ns
Groeneveld, 2007 | Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals | To determine if VAMCs with higher proportions of black inpatients performed fewer cardiac procedures or had larger racial differences in procedure rates than predominantly white VAMCs. | retrospective cohort study | 300614 | National VA database | | Black v. white | hospitalization record or other VA hospital records. | 4 procedures were selected based on volume of use: bioprosthetic aortic valve replacement (AVR), ICD implantation, DCP implantation, and PCI (PCTA or stenting). | VA database of hospital admissions and outpatient care. Non-VA Medicare procedure use data from Va-Medicare merged files. | Multivariate logistic regression | | Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI 45029 blacks 255585 whites | DCP | ns | ns | 0.54, p<0.001 | 0.69, p=0.003
Groeneveld, 2007 | Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals | To determine if VAMCs with higher proportions of black inpatients performed fewer cardiac procedures or had larger racial differences in procedure rates than predominantly white VAMCs. | retrospective cohort study | 300614 | National VA database | | Black v. white | hospitalization record or other VA hospital records. | 4 procedures were selected based on volume of use: bioprosthetic aortic valve replacement (AVR), ICD implantation, DCP implantation, and PCI (PCTA or stenting). | VA database of hospital admissions and outpatient care. Non-VA Medicare procedure use data from Va-Medicare merged files. | Multivariate logistic regression | | Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI 45029 blacks 255585 whites | ICD | 0.65, p<0.001 | ns | 0.54, p<0.001 | 0.75, p=0.04
Groeneveld, 2007 | Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals | To determine if VAMCs with higher proportions of black inpatients performed fewer cardiac procedures or had larger racial differences in procedure rates than predominantly white VAMCs. | retrospective cohort study | 300614 | National VA database | | Black v. white | hospitalization record or other VA hospital records. | 4 procedures were selected based on volume of use: bioprosthetic aortic valve replacement (AVR), ICD implantation, DCP implantation, and PCI (PCTA or stenting). | VA database of hospital admissions and outpatient care. Non-VA Medicare procedure use data from Va-Medicare merged files. | Multivariate logistic regression | | Candidates for bioprosthetic aortic valve replacement, implanted cardioverter/defibrillator (ICD), dual-chambered pacemaker (DCP), and PCI 45029 blacks 255585 whites | PCI | 0.86, p=0.04 | ns | 0.69, p<0.001 | 0.67, p<0.001
Hassapoyannes, 2006 | Apparent racial disparity in the utilization of invasive testing for risk assessment of cardiac patients undergoing noncardiac surgery. | To assess race as a predictor of utilization of diagnostic cardiac procedures, before and after adjustment for demographic and clinical factors using the setting of elective evaluation of known, stable, cardiac patients undergoing noncardiac surgery, where the surgeon/anesthesiologist’s personal interest precludes expression of potential racial bias. | Secondary data analysis of prospective cohort study | 314 | WJB Dorn VAMC | Secondary analysis of prospectively collected data from 314 consecutive patients with stable, known cardiac disease who underwent preoperative evaluation prior to noncardiac surgery at the WJB Dorn VAMC from 1988 to 1992. Eligible were patients with assessment of the ejection fraction within 6 months prior to surgery and with 1) history of CAD documneted by coronary angiography, nuclear imaging, exercise stress testing, or electrocardiographic or enzymatic evidence of MI, 2) history of congestive heart failure or cardiomyopathy with ejection fraction <45%, or 3) history of significant arrhythmias | Black v. white | Not reported | 1) Utilization of invasive (coronary angiography) and noninvasive diagnostic procedures (treadmill stress testing, myocardial scintigraphy, 24-h Holter monitoring, echocardiography, or blood pool scintigraphy); 2) all-cause and total cardiac mortality, and cardiac morbidity | Prospective followup extended postoperatively for 30 days or until discharge; not otherwise specified. | Multivariate logistic regression | Age, congestive heart failure, previous MI, ongoing angina pectoris, shorter distance from residence to VAMC, cardiomyopathy, | Patients with CAD >99% male 92 blacks 222 whites | There were no racial differences in the use of noninvasive cardiac procedures but blacks used catherization less frequently. Race was a strong independent predictor of having coronary angiography for the total cohort and for patients with CAD alone, adjusted OR (95%CI) comparing black v. white (referent) = 0.10 (0.04–0.26). The proportion of patients who had CA was lower among blacks v. whites before adjustment for CAD (8.7% v 50%, p=0.0001) and after adjustment for CAD (11.8% v 61.4%, p=0.001). Race was no longer a significant predictor of CA in the model when patients with both CAD and cardiomyopathy were included, as a surrogate for disease severity. Race was not significantly predictive of mortality or morbidity. | | | | | The prevalence of ischemic cardiomyopathy was 2.64-fold higher among whites (29.8%) than blacks (15.7%). In the multiple logistic regression model, when both presence of CAD and cardiomyopathy were factored in as a surrogate of suspected severity of disease, black race ceased to be an independent predictor of underuse of catheterization. Author therefore suggests that the lower rate of CC in blacks may be related to epidejiologic differences. Author comments that racially similar mortality and morbidity after noncardiac surgery indicate no underuse of cardiac diagnostic procedures among blacks.
Horner, 2007 | Factors associated with a provider’s recommendation of carotid endarterectomy: implications for understanding disparities in the use of invasive procedures | To assess the relative importance of clinical and nonclinical factors in a provider’s decision to recommen carotid endarterectomy (CEA) for a patient, with emphasis on the role of the patient’s race in the provider’s assessments of the risks and benefits of the procedure. | 2nd data analysis | 355 | 5 VAMCs | Eligible patients had been idenitifed from among the 4677 patients who were referred for carotid ultrasonography at any of the 5 sites btw 1997–1999 (n=708). See [Oddone, 2002 #1864] The current study focused on a subset of 355 patients who were preoperatively adjudicated as appropriate candidates for CEA per the RAND criteria. Analysis was limited to 251 patients with complete data. | Black v. white | Self-report | Primary outcome was provider’s recommendation that the patient receive CEA. | Medical record review and ascertainment of clinical status, with 6 month follow-up contact. | Multivariable logistic regression | Patient factors: age, race, degree of carotid artery stenosis, clinical status, trust in the provider, and aversion to surgery. Provider factors: assessment of the patient’s risks and benefits from CEA, including perceived efficacy of the surgery, perceived risk of stroke <=1 year without the surgery, and perceived risk of stroke <=30 days from surgery. | Patients judged appropriate for CEA 10.4% black 89.6% white | The primary factor associated with a provider’s decision to recommend CEA was his or her assessment of the patient’s risk of stroke without the surgery. Patient’s race was not associated with provider’s assessments of the patient’s risks or benefits from CEA. Adjusted relative odds (95%CI) of recommending carotid endarterectomy associated with race: African American 0.65 (0.25–1.73), p=ns The relationships between each of the providers’ assessments of the risks and benefits of surgery and the recommendation to have surgery was similar in both patient race groups. However, comparison of black and white patients on the various provider-perceived risks and benefits indicated that a relatively greater proportion of the black than white patients was perceived to benefit from CEA, whereas the risk from the surgery was perceived as “high risk” in a similar proportion of whites and blacks. | | | | | Patient-related factors such as aversion to surgery and trust in the provider were not associated with the provider’s recommendation. 28.9% of patients for whom CEA was recommended never had the surgery; the patient’s race was unrelated to the decision not to follow the provider’s recommendation about CEA. Author’s conclusion: findings suggest that a provider’s recommendation about the invasive procedure of CEA is based on the provider’s assessment of the procedural benefit for the patient and that assessment is independent of the patient’s demographic characteristics. Author suggests future research on the factors that determine the provider’s assessment of the patient’s risks and benefits, including exchange of information regarding signs and symptoms of disease, and thereapeutic options available.
Ibrahim, 2003 | Racial/ethnic variations in physician recommendations for cardiac revascularization | To examine physician recommendations for revascularization among African American and White patients who had coronary angiographies (cardiac catheterization) at 2 health care facilities: one VA and one non-VA hospital | cross-sectional survey | 792 | 1 VA hospital and 1 non-VA hospital in the same NE city. | All patients scheduled for coronary angiography at a single VA hospital and a university hospital in the same city during 1997–1999. Both are tertiary care centers affiliated with a university program that performs PTCA and CABG. Excluded transplant patients, patients scheduled for intervention angioplasty, and those undergoing primary or emergency angioplasty. All consecutive elgible patients were approached by a research assistant, except in instances in which multiple procedures performed simultaneously prevented all such patients from being approached; in these cases, the research assistant preferentially approached patients who appeared to be African American. This report includes only patients who had at least one significant stenosis, defined as >= 70% of any single epicardial vessel or >=50% in the left main coronary artery. Patients were invited by phone to participate in the study. 46 cardiologists and cardiology fellows from the 2 sites were interviewed. | Black v. white | Self-report | The primary outcome analyzed in this study was the cardiologists’s response to the question “Would you recommend revascularization for this patient?” (Yes/no) In cases wehre the patient was not offered revascularization, cardiologists were asked to indicate a reason why either PTCA or CABG was not recommended. Response options included insignificant amount of myocardium at risk, insignificant disease, coronary anatomy is such that the chances of technical success are low, surgical risk is excessive, social situation makes intervention not feasible, and patient likely to refuse. Write-in response also available. | Patient interview: structured and semistructured questionnaires were used to gather information from patients. | Multivariate logistic regression | gender; clustering of patients under cardiologists (random effect for cardiologist) was considered but nonsignificant, so removed; age, educational level, self-assessed health status, history of revascularization, disease severity, and procedure site. | Underwent coronary angiography 54 blacks 738 whites | Adjusted OR (95%CI) of black vs. white patients receiving recommendations, by site of coronary angiography procedure, adjusted for age, disease severity, history of revascularization, educational level, and health status: VA hospital: 0.31 (0.12–0.77) University hospital: 1.69 (0.69–4.14) Most frequent reasons for not recommending revascularization at the VA site, black v. white (number and %): PTCA Insignficant mycardium at risk 9 (33%) black v. 95 (30%) white Low chance of technical success 7 (26%) black v 92 (29%) white Additional testing needed 4 (16%) black v 93 (11%) white CABG Insignificant myocardium at risk 7 (26%) black v 101 (36%) white CABG not technically feasible 5 (16%) black v 64 (21%) white Additional testing needed 2 (7%) black v 37 (12%) white | | | | | Physician recommendations for revascularization varied by patient race only at the VA site. No differences in revascularization recommendations by patient race were found at the private university hospital. Cardiologists at the VA site were less likely to recommend revascularization (PTCA or CABG) to black patients than to white patients. This difference was not accounted for by differences between the 2 groups in disease status (number of stenotic vessels) or patient age, education level (a marker of SES), previous revascularization, or self-rated health status. However, reasons for not recommending PTCA or CABG were generally similar in type and frequency for both blacks and whites. Explanatory mechanisms on patient or provider level were not studied.
Kressin, 2002 | Racial differences in health-related beliefs, attitudes, and experiences of VA cardiac patients: scale development and application | To examine whether there are racial differences in health related beliefs, attitudes, and experiences among veterans with noninvasive test results suggesting the presence of coronary artery disease. | Cross-sectional survey | 854 | 5 large, urban VAMCs (same study as Kressin 2004) | Included patients with positive nuclear imaging studies indicating cardiac ischemia between 1999–2001. Excluded patients if they had CC, any revascularization, or heart transplant surgery in preceding 6 months; participated in a clinical trial that determined cardiac treatment; if race was other than white or black; or if cognitive status was impaired. | Black v. white | Self-report | used Health Decision Model, results from focus groups and literature, and investigators’ own decisions about relevant domains to develop scales to assess 8 dimensions of health attitudes, beliefs, and experiences, including disease severity, patient evaluations of physicians’ interpersonal style, patient evaluations of VA care, attitudes toward religion, satisfaction with treatment decision making, perceived urgency of CC, vulnerability to CC, and bodily impact of CC. Compared differences by race. | 2 self-administered questionnaires: 1 completed after patient received their nuclear imaging study (n=854) and a 2nd completed after patients received the results from their nuclear imaging study (n=832). | multitrait-scaling analysis to determine which survey itemrs best measured the hypothesized dimensions of health beliefs; Chi2 analyses for racial differences among individual health attitude items | None | Patients with cardiac ischemia 98% male 175 blacks 679 whites | Racial differences in scale scores, white v. black (p-value): Disease severity: 68.8 v 68.8 (ns) Patient evaluation of physicians: 76.9 v 76.3 (ns) Evaluation of VA care: 75.4 v 75.2 (ns) Attitudes toward religion: 69.1 v 77.8 (p<0.01) Satisfaction with decision-making: 73.0 v 75.9 (p=0.09) Perceived urgency of catheterization: 78.5 v 75.6 (ns) Vulnerability to catheterization: 17.7 v 21.7 (ns) Bodily impact of catheterization: 55.1 v 53.8 (ns) Individual Health Attitude Items: Blacks were less likely to have been encouraged by friends and family to have a catheterization (p<0.05) and were less likdely to report that their family or friends had had catherization (p<0.01) or that they themselves had had previous experiences with surgery in general (p<0.01) Blacks were more likely to indicate that nodecision had been made yet about having a CC (p<0.02) | | | | | Very few differences were observed between black patients and white patients in the 8 domains. Authors conclude that these data provide little support for the theory that racial differences in patients’ beliefs and attitudes toward health care in general, and coronary disease, are strongly associated with discrepancies in procedure use. Racial differences were observed only in attitudes toward religion, in that black patients placed stronger importance on God and religion in general, as well as in coping with their heart problems and in making decisions about treatment for their heart disease. Blacks were less likely to report that family/friends had had CC and less likely to have been encouraged by family/friends to have a CC.
Kressin, 2004 | Racial differences in cardiac catheterization as a function of patients’ beliefs | To examine whether there were racial disparities in the use of cardiac catheterization (C-CATH) in a cohort of 1045 white and black patients at 5 VAMCs whose nuclear imaging studies indicated reversible cardiac ischemia, and if so, to comprehensively examine whether patients’ attitudes and beliefs or physicians’ assessments and perceptions about patients could explain this racial disparity when controlled for the effects of clinical and sociodemographic characteristics. | Prospective cohort study | 1045 | 5 large urban VAMCs with onsite C-CATH facilities | Patients with a positive nuclear imaging study between 1999–2001. Excluded impaired mental status, participants in another research study determining their cardiac treatment, race other than white or black, had a cardiac procedure in the preceding 6 months, non-veterans. 76% response rate among those eligible. Among excluded patients, 29% were black vs. 23% in those included in the study (p=0.003). This is the same cohort studied in Kressin 2002, but sample size differs. | Black v. white | Self-report | Patient questionnaire measured demographics, the Seattle Angina Questionnaire, beliefs and attitudes about health and health care received (physician’s capabilities and interpersonal style, evaluation of VA care, and patients’ attitudes toward religion and its role in dealing with cardiac disease and treatment decision making, medical skepticism, generalized trust in people, optimism, and prior experiences of racial and social class discrimination). Physician questionnaire asked clinical assessments and perceptions about patients’ personal characteristics (good communicator, high SES, independent, intelligent, knowledgeable, likely to underreport pain or comfort, likely to show up for followup appointments, likely to comply with medication, likely to participate in cardiac rehabilitation if recommended). | Chart review; 2 self-administered questionnaires: 1 within 4 weeks after patients’ nuclear imaging study, and 1 after the patients reported that they had received the study results. Patients were contacted by the research assistant in person or by telephone. For each patient, the physician who ordered the nuclear study was also asked to complete a survey. | Logistic regression for odds of receiving C-CATH by race | Sociodemographic variables, clinical variables, health belief variables, and physician assessment/perception variables | Patients with cardiac ischemia 98% male 236 blacks 809 whites | 33% of blacks and 47% of whites received C-CATH (p=0.0002). Attitudes and beliefs, mean score on scales 0–100 with higher values indicating a higher degree of what the statement described, blacks v. whites: Blacks more frequently indicated reliance on religion as a way of coping with their heart disease and treatment decisionmaking: 78.44 v 68.93, p<0.001 Blacks indicated less trust in people: 41.76 v 60.28, p<0.0001 Blacks were more likely to report experiences with racial (36.42 v 5.01, p<0.0001) and social class discrimination (19.68 v 13.82, p=0.01) Blacks were less likely to agree that they could overcome illness without help from a medically trained professional: 2.16 v 2.40, p=0.006. Physicians felt the necessity/importance of C-CATH was nonsignificantly greater for white patients (lower values = more importance): 2.59 v 2.76, p=0.11. Physicians rated whites’ pretest probability of CAD higher than blacks: 74% v 66%. Physicians rated white patients as better communicators, of higher SES, and as more likely to comply with medication treatment than blacks. OR (95%CI) of whites v. blacks receiving C-CATH were significantly increased after adjusting for sociodemographic variables, clinical variables, and health belief variables: 1.79 (95CI 1.12–2.86), p=0.15. Adding physician’s variables to the model decreased the sample size to 56% of the full sample due to limited response rate from physicians. The adjusted OR decreasd to 1.20 (95%CI 0.55–2.62) and was no longer signiifcant. This indicates that | | | | | Significantly more whites received C-CATH than blacks. Blacks indicated a greater reliance on their religion or God in coping with and making decisions about their cardiac treatment than did whites. Blacks indicated less generalized trust in people and more experiences of racial and class discrimination. Patients’ health beliefs, however, did not explain the observed racial differences but physician’s assessments of patients did explain some of the variation. Physician’s ratings of CAD and the importance of C-CATH for a patient were both higher for white patients, and these variables contributed to the observed racial disparities in C-CATH use beyond what could be attributed to clinical differences identified by chart review. The study methods are identical to Kressin 2002, but number of subjects is greater in the more recent study because more cumulative subjects were included.
Lowry, 2005 | Intentional and unintentional nonadherence to antihypertensive medication | To examine associations between patient characteristics, including reported adverse effects, and both intentional and unintentional nonadherence among 588 hypertensive patients | Cross-sectional survey | 588 | Durham VAMC: V-STITCH RCT to improve control of HTN | RCT study population: Individuals treated for hypertension at the Duram VAMC primary care clinic, who had at least one prescription filled for antihypertensive medication in the prior year of enrollment (2000–2002). | non-white vs. white | Self-report | Intentional and nonintentional nonadherence to hypertensive medications | Morisky self-report scale: 4 statements describing nonadherence to drug therapy, including “I sometimes forget/am careless about taking my blood pressure medicine (unintentional); when I feel better I sometimes stop taking BP medicine; if feel worse when I take the BP medicine, sometimes I stop taking it (intentional). | Logistic regression | education level, race, financial status, comorbidity of diabetes mellitus, and number of reported adverse effects. | 588 hypertensive patients 42.5% nonwhite | Adjusted OR (95%CI) for intentional nonadherence, non-white v. white; 2.87 (1.55–5.28), p<0.001 Adjusted OR (95%CI) for unintentional nonadherence: 1.77 (1.23–2.56), p<0.001 | | | | | Study found more nonadherence both intentional and non- intentional among nonwhites. Non-whites were 2.9 times more likely to report intentional nonadherence than whites. Non-whites were 1.8 tmes more likely to report unintentional nonadherence.
Maynard, 2006 | The use of percutaneous coronary intervention in black and white veterans with acute myocardial infarction | To determine if black veterans with AMI are less likely to receive PCI than whites, in the era of drug eluting stents. | Retrospective cohort study | 4209 | Part of VHA External Peer Review Program | Included veterans admitted to VAMCs for AMI between 2003–2004. Excluded patients who had AMI while hospitalized for another medical condition. Excluded race other than black or white. | Black v. white | Administrati ve data: peer review database and VA workload files | Rates of CC performed <=30 days after admission; rates of PCI performed <=12 hours from admission. | Chart abstraction; workload data from the Austin Automation Center was accessed to determine cardiac procedure use after discharge. | Logistic regression, backward stepwise to select predictors of PCI use | History of cerebrovascular disease, renal disease, COPD, dementia, chest pain on admission, ST elevation on the admission ECG, prolonged chest pain, age, geographic region, and availability of PCI services at the admitting hospital | Veterans admitted for AMI >98% male 680 blacks 3529 whites >25% unknown race | Bivariate analyses: Blacks v. whites rates of CC <=30 days after admission were similar (59% v 57%, p=ns) as was PCI <=12 hrs afer admission (8% v 8%). A significantly lower proportion of blacks received PCI <=30 days after admission: 32% v 40%, p<0.0001. Fewer blacks received CABG <=30 days from admission: 5% v 8%, p=0.001. Among those who underwent CC, the proportion of PCI was still lower among blacks: 48% v 59%, p<0.0001). Adjusted OR (95%CI) for each procedure, blacks vs whites (referent): Blacks had a 21% lower likelihood of undergoing PCI: 0.79, 95%CI 0.71–0.88 Results from further adjustment for clustering of patients within medical centers were similar. | | | | | Racial disparities in the use of PCI within 30 days after admission exist. Authors note that given the equivalent use of cardiac catheterization as well as the equivalent use of PCI within 12 hours of admission, it is possible that less extensive or minimal coronary artery disease in blacks could explain the observed difference. The proposed mechanism was not explored in this study.
Mickelson, 1997 | Acute myocardial infarction: clinical characteristics, management and outcome in a metropolitan Veterans Affairs Medical Center teaching hospital | To examine the influence of race and age on the use of thrombolytic therapy, invasive cardiac procedures, and subsequent outcomes in a VA teaching hospital. The influence of Q wave evolution on the use of invasive cardiac procedures and outcome was also assessed | Retrospective cohort study | 353 | Houston VAMC | Malesadmitted for MI, selected by chart review at Houston VAMC during FY 1994–1995 | Black, Hispanic, v. white | Chart review | If treatment was withtheld, the reasons for omission were determined. | Chart review; presence of comorbidities determined from PTF | Multiple logistic regression | Age, comorbidities | Men admitted for MI 84 blacks 37 Hispanics 232 whites | Proportion of patients that received each procedure: CC: 63% whites, 51% blacks (p<0.05), 57% Hispanics PTCA: 23.3% whites, 17% blacks, 19% Hispanics (p=ns) CABG: 10.3% whites, 7.1% blacks, 16% Hispanics (p=ns) Adjusted OR for each procedure, whites as referent group: Thrombolytic use: blacks 0.64 (0.28–1.49), Hispanics 0.29 (0.10–0.85) CC: blacks 0.59 (0.35–1.02), Hispanics 0.76 (0.35–1.67) Adjusted OR for in-hospital death, whites as reference: Blacks: 1.59 (0.73–3.47) Hispanics 2.68 (1.03–7.00) | | | | | There were no racial differences in use of thrombolytic therapy. CC was performed less among blacks but with marginal significance. Increased mortality was observed among blacks and Hispanics but not to significance.
Mirvis, 1994 | Variation in utilization of cardiac procedures in the Department of Veterans Affairs health care system: effect of race | To determine whether racial differences existed in utilization rates for cardiac catheterization and cardiac surgery in the VHA | Retrospective cohort study | 83001 | National VA database | Patients discharged with diagnoses of CAD or valvular heart disease in 1991. | Black v. white | PTF | CC, cardiac surgery. Utilization rates computed for each race group as N patients undergoing procedure for each 1000 patients of that race admitted to a VAMC. | PTF | Multiple logistic regression | age, gender, presence of diabetes mellitus, hypertension and peripheral vascular disease, a computed comorbidity score, hospital region, hospital complexity group and local presence of catheterization and cardiac surgical facilities. | CAD, n=30,300: 3670 blacks 26630 whites Valvular HD, n=1335: 141 blacks 1194 whites | Coronary artery disease, procedures per 1000 cases, black v. white: CC 433.2 v. 503.4, p<0.001; Cardiac surgery 124.5 v 179.0, p<0.001. Valvular heart disease, procedures per 1000 cases, black v. white: CC 432.6 v 575.4, p<0.001; cardiac surgery 354.6 v. 423.8, p=ns. Among patients undergoing CC, 35.6% of whites v 28.7% of blacks underwent surgery. Adjusted ORs: whites with CAD had a significantly greater likelihood of undergoing CC (adjusted OR 1.63, 95%CI~1.5–1.75) and cardiac surgery (adjusted OR 1.65, 95%CI~1.48–1.8) compared with blacks. Among patients with valvular heart disease, the likelihood of CC and cardiac surgery was higher for whites than blacks: adjusted OR 1.49 for cardiac surgery (95%CI 1.02–2.18), CC ~1.98 (95%CI~1.35–2.9) Variations were observed by region and by hospital size and complexity. | | | | | This study observed higher rates of catheterization and surgery in white than black patients. Significant differences existed for some but not all levels of hospital complexity for both coronary and valve disease, and for both CC and surgery. Authors note: the existence of racial differences is a complex phenomenon that is dependent on the interaction of numerous variables including the type of disease, the procedure studied, the geographic region, and the complexity level of the local VA facility. Explanatory mechanisms not studied.
Mirvis, 1998 | Impact of race and age on the effects of regionalization of cardiac procedures in the Department of Veterans Affairs Health Care System | To examine the impact of regionalization on rates of cardiac catheterization, PTCA, and CABG in 2 subgroups of patients - the elderly and African Americans - treated in the VHA. | Retrospective cohort study | 30245 | National VA database | Included patients with a primary diagnosis of any form of CAD in FY 1994. Info about the primary service area and the presence or absence of a CC laboratory and cardiac surgical program in the local VA was determined for each patient. | Black v. white | PTF | CC, PTCA, or CABG at any time during fiscal year 1994, among patients with CAD during FY 1994, comparing whether a CC lab or cardiac surgical program was present vs absent in patient’s service area. | PTF | Multiple logistic regression | Age, gender, type of CAD (acute/chronic) computed Charlson comorbidity index | Men and women admitted to a VAMC for CAD 3652 blacks 26593 whites | Adjusted OR (95%CI) for each procedure within each race group, comparing presence vs absence (referent) of a catheterization lab in patient service area; p- value compares ORs btw whites and blacks CC for whites 1.86 (1.76–1.96); for blacks 1.92 (1.61–2.30), p-value = 0.174 PTCA for whites 1.31 (1.21–1.43); for blacks 1.78 (1.25–2.54), p-value <0.001 CABG for whites 1.14 (1.05–1.22); for blacks 1.48 (1.05–2.09), p-value <0.001 Adjusted OR (95%CI) for each procedure within each race group, comparing presence vs absence (referent) of a cardiac surgical program in patient service area; p-value compares ORs btw whites and blacks CC for whites 1.64 (1.56–1.73); for blacks 1.75 (1.53–2.01), p-value = 0.008 PTCA for whites 1.46 (1.35–1.57); for blacks 1.68 (1.30–2.16), p-value <0.001 CABG for whites 1.41 (1.31–1.51); for blacks 1.80 (1.38–2.35), p-value <0.001 | | | | | The presence of a cardiac catherization laboratory and a cardiac surgical program in the local VA facility significantly increased the likelihood that patients with CAD would undergo CC, PTCA, and CABG. The odds (presence vs absence of a CC facility) for blacks were significantly greater than those for whites for PTCA and CABG, but not for CC. The odds (presence vs absence of a cardiac surgical program) was greater for blacks than whites for CC, PTCA, and CABG, indicating that the effect of having a local cardiac surgical program was greater for blacks than for whites.
Oddone, 1993 | Racial variations in the rates of carotid angiography and endarterectomy in patients with stroke and transient ischemic attack | To determine racial variations in the rate of carotid angiography and endarterectomy in the VHA | Retrospective cohort study | 35,922 | National VA database | Males aged 45+ discharged from any VA hospital 1988–1989 with a diagnosis of ischemic stroke or TIA. | Black, Hispanic, v. white | PTF | Date of angiography and subsequent carotid endarterectomy; hospital admissions up to 12 months after index hospitalization were tracked for outcomes, and 3 years prior were examined for admissions for TIA or stroke. | PTF | Multiple logistic regression | Age, service-connected disability, region, comorbidities, clinical status (TIA vs stroke), clinical history (previous stroke or TIA within 3 years prior), HTN as a secondary discharge diagnosis, and Charlson comorbidity index. | Men hospitalized for stroke or TIA Aged 45+ 27690 whites 6526 blacks 1162 Hispanics 544 Other race | Unadjusted proportion per 100 patients for each procedure v. whites; Adjusted risk ratio RR (95%CI), whites as referent group, by outcome: Angiography: Blacks 5.3% v 11%; 0.47 (0.42–0.53) Hispanic 8.3% v 11%; s 0.78 (0.63–0.98) Carotid endarterectomy (proportion per 100 patients who underwent angiography): Blacks 14.9% v 38.1%; 0.28 (0.20–0.38) Hispanics 22.7; v 38.1%; 0.45 (0.28–0.73) | | | | | Race was a strong predictor of receiving carotid angiography and carotid endarterectomy. Blacks received CA at less than half the rate of white pateints. Hispanics received CA at a rate 20% below white patients. Blacks were one-third as likely as whites to receive CE. Hispanics were less than half as likely as whites to subsequently receive CE.
Oddone, 1998 | Understanding racial variation in the use of carotid endarterectomy: the role of aversion to surgery | To determine if differences in aversion to carotid endarterectomy might account for some of the racial difference in utilization of this procedure. | Cross-sectional survey | 90 | 4 VAMCs | Patients were selected from a retrospective cohort of patients hospitalized for stroke, TIA, or carotid artery imaging who were assembled to assess racial differences in clinical factors that could affect process of care, including use of CEA. Included black and white male patients age >=45 discharged alive between 1991–1995 from 4 VAMCs. Patients were mailed a survey form. Telephone contact was attempted within 2 weeks. 82.6% responded of 62% contacted. | Black v. white | Self-report | Telephone survey covered 6 areas: sociodemographics, cognitive impairment, prior surgical experiences and discussions about CEA with their physiican, functional status, patients’ perceptions of current health status using time trad- off technique, and patients’ aversion to CEA using a standard gamble technique. | Patient interview and medical record review | Multivariate linear regression, outcome excess risk score (=aversion to CEA) | prior history of surgery and patient preferences for their current health state (lower score indicates lower point of indifference between length of time in excellent health vs. 10 years in current state = lower perceived value for current health status.) | Males hospitalized for stroke or TIA, or carotid artery imaging 44 blacks 46 whites | Blacks and whites were similar in functional status (Barthel index score) and perceptions of current health status. Blacks were willing to accept more excess risk of death to avoid CEA compared with whites: median excess risk 20% for blacks, 2.5% for whites (p=0.01). A smaller proportion of blacks than whites had prior surgery of any type: 73% v 94%, p=0.01. In a multivariate model, race, prior history of surgery, and current helath state were all significantly associated with aversion to CEA. Blacks, patients with no prior history of surgery, and patients who reported lower values for their current health state showed higher aversion to CEA. | | | | | CEA is performed primarily to reduce future risk of stroke, rather than to reduce current suffering. Blacks appear to have a stronger aversion to CEA than do white patietns. Prior surgical experience and patients’ perceptions about their current health state play a role in this aversion, independently of race.
Oddone, 1999 | Race, presenting signs and symptoms, use of carotid artery imaging, and appropriateness of carotid endarterectomy | To determine racial differences in use of carotid artery imaging and to ascertain racial differences in presenting signs and symptoms and overall appropriateness for carotid endarterectomy (CE) | Retrospective cohort study | 803 | 4 VAMCs | Patients aged 45+ hospitalized btw 1991–1995 at 1 of 4 VAMCs, for diagnoses of TIA, ischemic stroke, or amaurosis fugax. Excluded if medical record had insufficient information to determine clinical status, or asymptomatic. | Black v. white | Chart abstraction | Noninvasive (Doppler ultrasound) and invasive carotid angiography tests to evaluate the degree of carotid artery stenosis. Also determined operative risk via Sundt Index; appropriateness of CE. | From chart abstraction, recorded whether pt had received neuroimaging during index hospitalization (CT or MRI). If so, noted whether noninvasive (Doppler ultrasound) and carotid angiography tesets to evaluate degree of carotid artery stenosis. | Multiple logistic regression | Age, Charlson comorbidity, clinical presentation (TIA/minor stroke/major stroke), anticipated operative risk, and hospital. | Patients hospitalized for stroke or TIA aged 45+ 389 blacks 414 whites | Significantly fewer blacks with TIA received either noninvasive or invasive studies of carotid arteries during index admission or within 6 months after: 83% v 94%, p=0.003; Coppler ultrasound: 76% v 89%, p<0.001 Carotid angiography: 27% v 49%, p<0.01 All stroke patients received either CT or MRI of the head during hospitalization (98.1% of blacks v 99.6% of whites, p=ns). Use of carotid ultrasound or Doppler was racially similar: 60.1% of blacks v 65.2% of whites, p=ns. Fewer blacks had carotid angiography: 7.9% v 13.9%, p=ns. Adjusted OR (95%CI) for receiving carotid artery imaging, blacks as referent: Whites: 1.50 (1.06–2.13) Appropriatness for CE: Of 57 whites classified as CE-appropriate, 38 (67%) underwent CE, whereas 5 of the 10 blacks (50%) classified as CE-appropriate underwent the procedure. The RR of CE for whites compared with blacks was 1.34 (0.70–2.53), among patients classified as CE-appropriate. Among patients classified as uncertain, 24% of whites received CE, v 3% of blacks: RR 9.2, 95%CI 1.26–66.7. | | | | | Whites were 50% more likely to be imaged than blacks. Author notes that adjustment for appropriateness of CE reduces but does not eliminate the influence of race.
Oddone, 2002 | Carotid endarterectomy and race: do clinical indications and patient preferences account for differences? | To determine the importance of clnical indications and patient preferences in predicting the use of carotid angiography and carotid endarterectomy (CE) in a racially stratified sample of patients. | Prospective cohort study | 708 | 5 VAMCs | Patients were enrolled after a carotid ultrasound/Doppler study at 5 VAMCs between 1997–1999. Patients were eligible if the ultrasound revealed at least 50% stenosis in a carotid artery. Excluded patients who had previously had CE, poor mental status, race neither white nor black. Patient interviews were conducted at the time of the index carotid ultrasound, and each patient was followed up for 6 months to determine clinical events and receipt of carotid angiography or CE. | Black v. white | Self-report | Primary outcome: receipt of either carotid angiography or CE within 6 months of the carotid ultrasound. Measures obtained from patients: aversion to CE, trust in physician, prior surgical experience, health- related QOL Measures obtained from medical record: neurological status, appropriateness for CE, comorbid illness. | Medical records; patient interview after carotid ultrasound/Doppler study, and 6 month followup. | Multiple logistic regression for receipt of CE or carotid angiography | RAND appropriateness, aversion to CE, surgical experience, self-rated health, medical comorbidities, and site. | Patients with >=50% stenosis in a carotid artery >98% male 91 blacks 617 whites | Previous surgical history was more frequent among whites than blacks: CABG 15.8% v 13.2; Any surgery 71.6 v 59.3%, p<0001 Aversion to CE was significantly higher among blacks (p=0003). Among blacks, 31% of responses were in the highest aversion score quartile, compared with 15% of whties. Appropriateness scores for CE were similar between blacks and whites. More whites were in the higher operative risk stratum for CE: 15% of blacks v 29% of whites (p=0.008) 6 month followup was 94%. There were no significant racial differences in receipt of carotid angiogram or CE within 6 months of index ultrasound, either in unadjusted analysis or when patients were separated into appropriateness categories. Use of carotid angiogram, black v white: 17% v 20% (p=ns) Use of carotid endarterectomy, black v white: 14% v 20%, p=ns Use of either carotid angiography or endarterectomy, black v white: 23% v 30% (p=ns) Adjusted OR for CE among patients with >=50% stenosis in a carotid artery, blacks as referent: whites 1.0 (95%CI 0.5–2.2) p=ns Aversion to the procedure was not associated with receipt of CE (p=0.13). There was no difference by race in receipt of CE within appropriateness categories. Only RAND | | | | | Black and white patients were equally likely to receive CE. Despite that blacks had a greater aversion to CE, this difference did not influence receipt of CE. Clinical status was the primary determinant of the receipt of CE.
Ohldin, 2004 | Ethnic differences in satisfaction and quality of life in veterans with ischemic heart disease | To assess differences in self-reported health status and satisfaction between blacks and whites with IHD. | Cross-sectional survey | 7,985 | 6 VAMCs in the ACQUIP project | Patients enrolled in the General Internal Medicine clinic, identified using Vista database. Eligible were all patients assigned to a primary care provider between 1997–1999 and who made at least one visit during the prior year. Excluded VA employees and patients without a valid mailing address. Included only patients with angina who returned the SAQ. | Black v. white | Self-report | Health-related quality of life, measured by SF-36. SAQ: measures 5 domains of ischemic heart disease: physical function, anginal frequency, anginal stability, disease perception, and satisfaction with care. SOSQ measures the interpersonal skills of the provider. Organizational scale assesses satisfaction with overall quality of care and services - e.g. waiting time, ease of making appointments or refilling prescriptions. | Self-administered screening questionnaire, followed by Medical Outcomes Study 36-item Health Survey (SF-36); Seattle Angina Questionnaire. Seattle Outpatient Satisfaction Questionnaire (SOSQ). Questionnaires were sent by mail. | Multiple linear regression | Site, sociodemographic factors (age, age-squared, education, marital status, employment, income, and whether the patient received medical care outside the VA, comorbid illness = total number of additional conditions reported on the screening questionnaire (up to 21). | Patients with angina 1281 blacks 1801 whites | For unadjusted SOSQ scores, blacks reported lower satisfaction with providers (66 v 71.8, p<0.05) and lower satisfaction with organizational aspects of their care (58.6 v 61.5, p<0.05) compared with whites. After adjustment for sociodemographic variables and ethnicity-site interactions, scores were significantly lower among balcks for only two of the 6 sites, both located on the west coast. Blacks had lower mean adjusted scores for the organizational scale at only one of the 6 sites, but adjusted results from all sites combined were not statistically significant. Satisfaction specifically with angina treatment (SAQ) was lower for blacks at 5 of the 6 sites but results were only significant at 3 sites. | | | | | Ethnic differences in satisfaction with patients' providers and their medical treatment were site-specific. Blacks reported significantly lower satisfaction with care for their IHD compared with whites, but these differences persisted at 3 of 6 sites after adjustment for covariates. (Study compared demographic characteristics of respondents and nonrespondents. Respondents were more likely to report having undergone PCI or CABG, were less likely to smoke and have lower CAGE scores which is indicative of increased risk for alcohol abuse and dependence.)
Peniston, 2000 | Severity of coronary artery disease in black and white male veterans and likelihood of revascularization | To sample blacks and whites in the evenly distributed population in Wash. DC without the need to oversample blacks, to determine whehter there are racial differences in the use of invasive cardiac procedures. | Retrospective cohot study | 1460 | 1 VAMC (Washington, DC) | All records from 1986–1992 that included coronary angiography as part of the procedure from the inception of the file. Included black or white race. Excluded patients evaluated for complaints related to valvular heart disease, patients catheterized in preparation for an electrophysiologic study, females, and race other than black or white. | Black v. white | Administrative records | PTCA, CABG: whether recommended and/or received, by race. | Electronic medical records | Multivariate logistic regression | Survival analysis adjusted for age, race, ejection fraction, CHF, and whether CABG was performed. | Men who received coronary angiography 726 blacks 734 whites | The results of cardiac catheterization showed that blacks had almost twice the percentage of patients without significant CAD, compared with whites. Whites had greater proportions with 2-and 3-vessel, left main, and proximal left anterior descending CAD: all categories more likely to be referred for revascularization. Among both blacks and whites, only 60% of patients believed to be suitable for revascularization had PTCA or CABG within 6 months of the diagnostic study. Ethnicity had a significant univariate association with eventual revascularization but was not a significant independent predictor for revascularization by logistic regression. When the analysis was confined to only patients with significant CAD, ethnicity did not have a significant multivariate or univariate association with revascularization. Mean survival was poorer for blacks (3101 days) than whites (3346 days), p<0.001. Adjusted hazard ratio (05%CI) comparing whites to blacks: 0.57 (0.43–0.76) Adjusted HR among patients with significant CAD, whites v. blacks: 0.57 (0.43–0.80) % of patients who used procedures, black v white: PTCA 0.96 v 1.23 CABG 0.83 v 1.50 | | | | | There were no racial differences in the use of PTCA/CABG after cardiac catheterization. After coronary angiography, blacks and whites underwent revascularization procedures related to severity of disease. Blacks had significantly decreased survival beyond 2–3 years after cardiac catheterization, but there were no racial differences in earlier death. The decreased long-term life expectancy of black men is not explained by the presence of or treatment for CAD in this population.
Petersen, 2002 | Impact of race on cardiac care and outcomes in veterans with acute myocardial infarction | To assess racial differences in process of care for AMI (use of medications and invasive procedures) and outcome (short-term and long-term mortality) in the VHA. | Retrospective cohort study | 4611 | National VA database; sample included 81 sites | Included all males with a primary diagnosis of AMI in 1994–1995 using PTF; sampled patients from the 13,310 eligible patients, stratified by hospital cardiac service capability. VA facilities were classified in groups: 1) noncatheterization; 2) cardiac catherization-only have no revascularization capability; 3) cardiac surgery hospitals have all cardiac procedures available on-site. Group 1 was further divided into high v. low volume for AMI. Two subgroups of patients were further defined by coronary anatomy: 1) severe CAD; 2) left main or three-vessel disease. Excdlued DNR status, history of prior CABG, or a documented refusal of the procedure. | Black v. white | Chart review; PTF | Use of angiography, angioplasy, or bypass surgery during index hospitalization and within 90 days after. | Chart review. Catheterization reports were abstracted using RAND data forms. | Multiple logistic regression for mortality | Bivariate analyses for medication use and invasive procedures. For mortality: age, comorbidity, severity of illness, hospital (cardiac services, university affiliation) | Men with AMI 606 blacks 4005 whites | Medication use: blacks were less likely than whites to receive thrombolytic therapy at time of arrival; were equally likely to receive Beta-blockers at discharge. Blacks were more likely to receive ACE-inhibitorsand aspirin at discharge. Invasive procedures: Blacks and whites were similar in refusal of angiography during index admission (5.1% v 5.1%, p=ns) and in refusal of CABG (2.3% v 2.8%), p=ns). Use of angiography and PTCA during index admission and within 90 days was similar. Blacks were less likely than whites to undergo CABG during the index admission (3.6% v 7.0%, p<0.01) and within 90 days (6.9% v 12.5%, p<0.001). Total use, black v white: In subgroup of patients based on coronary anatomy, significantly more blacks refused CABG and fewer underwent CABG. Black v. white: Severe coronary artery disease: 11.6% v 4.3% refused CABG (p<0.005). Excluding those who refused, patients with DNR status, and history of CABG, 25.4 v 49.4% underwent CABG (p=0.001) Left main or three-vessel CAD: 12.2% v 4.6% refused CABG (p<0.005); Excluding those who refused, patients with DNR status, and history of CABG, 23.9% v 53.2% underwent CABG (p<0.001) Unadjusted and adjusted mortality at 30 days, 1 year, and 3 years after AMI were similar between races. | | | | | Blacks were equally or more likely than whites to receive certain medications or diagnostic coronary angiography. Racial disparities in use of thrombolytic therapy and CABG were found after accounting for differences in clinical presentation, clinical indications, and refusals. There were no racial disparities in short- term and long-term mortality up to 3 years after AMI.
Peterson, 1994 | Racial variation in cardiac procedure use and survival following acute myocardial infarction in the Department of Veterans Affairs | To examine whether blacks admitted to VAMCs with an acute MI are less likey than whites to undergo cardiac catherization or coronary revascularization procedures and to determine the impact of these differences on patient survival | Retrospective cohort study | 33641 | National VA database | All male veterans discharged alive or deceased from a VAMC with a primary or secondary diagnosis of an AMI during 1988–1990. Excluded patients admitted for noncardiac surgery who sufferend an AMI as a complication of surgery; excluded patients discharged with a diagnosis of AMI and a length of stay <5 days to exclude “rule out” AMIs. Excluded patients with CC, PTCA, or CABG in 90 days prior to admission for the AMI; excluded patients with a recent AMI admitted for subsequent care within 8 weeks of the acute episode. Excluded discharged abstracts with stays longer than 180 to exclude long-term VHA nursing home residents or residents of VHA domiciliaries. | Black v. white | PTF | CC, PTCA/coronary angioplasty, CABG within 90 days after admission for AMI; survival at 30 days, 1 year, and 2 years | PTF | Multiple logistic regression | Age, cardiac complications, number of secondary diagnoses coded, VAMC hospitalization in the preceding calendar year, the index hospital's geographic location, on-site availability of cardiac catheterization and bypass surgery, and the calendar year of the admission for the AMI. | Males discharged for AMI 4522 blacks 29119 whites | Adjusted OR (95%CI) for each procedure, comparing all blacks to whites (referent group) in AMI sample: CC within 90 d of AMI: 0.67 (0.62–0.72) CABG within 90 d of AMI: 0.46 (0.40–0.53) PTCA within 90 d of AMI: 0.58 (0.48–0.66) Any revascularization within 90 d of AMI: 0.46 (0.41–0.52) Adjusted OR (95%CI) for revascularization procedure among those who received CC: CABG: 0.59 (0.51–0.69) PTCA: 0.69 (0.58–0.82) Survival: Blacks were more likely to survive 30 days following AMI compared with whites: adjusted OR 1.18 (1.07–1.31). There was no sig. diff in adjusted 1-year survival; 2-yr survival was identical. Among those who received cardiac intervention (CC or revascularization procedures), blacks were more likely to survive 30 days compared with similarly treated whites: adjusted OR 2.14, 1.48–3.11; there were no sig. survival differences at 1 and 2 years, though survival estimates tended to be better for blacks. Among patients not receiving cardiac intervention, blacks were more likely to survive than whites at 30 days, 1 year, and 2 years. | | | | | After adjustment for patient and hospital characteristics, blacks wer 33% less likely than whites to receive cardiac catheterization and 64% less likely to undergo any coronary revascularization procedures with 90 days of admission for an acute infarct. Differences in revascularization rates persisted when the analysis was limited to patients who underwent cardiac catheterization. Despite undergoing significantly fewer cardiac procedures after AMI, blacks had better short-term and equivalent intermediate survival rates compared with whites.
Sedlis, 1997 | Racial differences in performance of invasive cardiac procedures in a Department of Veterans Affairs Medical Center | To analyze surgical referral patterns of a large, tertiary care VAMC, to explain potential reasons behind the racial differences in the utilization of invasive cardiac procedures in this setting. | Retrospective cohort study | 1796 | New York VAMC | All patients referred for cardiac procedures from 1988–1996 to NY-VAMC have already had CC and are potential candidates for surgery or angioplasty. | Black v. white | Administrative data | PTCA, surgery | Data from surgical referral conferences | Bivariate analysis | None | Patients who had CC and are potential candidates for surgery 322 blacks 1474 whites | Surgery was recommended more frequently for whites (59.8%) than blacks (46.6%, p=0.0022). PTCA was recommended equally for whites (19.3%) and blacks (17.7%, p=ns). Among patients recommended to undergo surgery, refusal of surgery was more common among blacks than whites: 9.4% of whites, 20.1% of blacks (p=0.0002) Among patients recommended for PTCA, refusal of PTCA was racially similar: PTCA refused: 2.1% of whites, 1.8% of blacks (p=ns) Similar racial disparities were observed at 3 different time points during the study period. | | | | | Author notes: racial differences in the performance of therapeutic invasive cardiac procedures are strongly related to a greater reluctance of blacks to agree to undergo these procedures, particiularly cardiac surgery. There does not appear to be any change over time in the degree of reluctance on the part of black patients to undergo cardiac procedures. These findings may help expalin in part the observed race-related disparities in cardiac care. The reasons for patient refusal were not documented. Authors suggest poor patient-provider communication, inadequate comprehension of the benefits of surgery or an exaggerated perception of the risk of surgery may be related to reluctance to undergo procedures. Intervention: author suggests more patient- directed education to eliminate such misunderstandings and minimize race-related inequities.
Whittle, 1993 | Racial differences in the use of invasive cardiovascular procedures in the Department of Veterans Affairs medical system | To examine the use of cardiac catheterization, PTCA, and CABG among whtie and black male veterans treated at VA hospitals. | retrospective cohort study | 428300 | National VA database | Included black and white males aged 31+ discharged from VA hospitals during 1987–1991 with primary diagnoses of CVD or chest pain. | Black v. white | PTF | CC, PTCA, CABG | PTF | Multiple logistic regression | primary discharge diagnosis (MI, unstable angina, angina, chronic ischemia, chest pain, or other CVD), age, coexisting morbidity, region, CABG center (whether the hospital was equipped to perform bypass surgery), year, and VA eligibility status. | Males aged 31+ hospitalized for CVD or chest pain 74570 blacks 353730 whites | Number of procedures per 100 blacks v. whites: CC 11.8 v 19.3 (p<0.05) PTCA 0.8 v 1.8 (p<0.05) CABG 1.6 v 5.0 (p<0.05) Adjusted OR (95%CI) for each procedure comparing whites to blacks (referent group), includes all discharge diagnoses: CC 1.38 (1.34–1.42) PTCA 1.50 (1.38–1.64) CABG 2.22 (2.09–2.36) | | | | | White patients consistently underwent invasive cardiac procedures more often than black patients, even after controlling for coexisting morbidity, demographic characteristics, and the treating hospital. The racial differences were greatest for CABG, smallest for CC, and intermediate for PTCA.
Whittle, 1997 | Do patient preferences contribute to racial differences in cardiovascular procedure use? | To determine whether patient preferences for the use of coronary revascularization procedures differ between white and black Americans. | Cross-sectional survey | 352 | Pittsburgh VAMC | 3 categories of male patients: 1) ambulatory patients without CAD (n=216), 2) ambulatory patients who previously underwent either PTCA or CABG; and 3) hospitalized patients who were awaiting a scheduled cardiac catheterization (CATH) for known or suspected CAD. Patients were identified while waiting appointments, or from the CATH schedule. | Black v. white | Self-report; patient survey | Patient responses to questions regarding: 1) willingness to undergo angioplasty or CABG if recommended by physician 2) whether they would elect CABG if it would a) improve sympotms but not survival, or b) if it would improve both symptoms and survival | Patient interview | Multivariate analyses | race, familiarity with procedure, inpatient status, history of previous procedure | 114 blacks 234 whites | Blacks were less likely to have had a previous revascularization or to be awaiting CATH; blacks were less familiar with each of the revascularization procedures. In multivariate analysis, measures of familiarity with the procedure were the most important predictors of attitude toward revascularization. Race was not a significant predictor of attitudes toward revascularization except for PTCA recommended by their physician: adjusted OR, whites v blacks: 1.69 (95%CI 1.03–2.79) | | | | | Whites were more likely to say they would undergo CABG if recommended, and that they would elect CABG if it would improve symptoms and survival, but much of the black-white difference in patient preferences seemed to be explained by questions that addressed familiarity with the procedures. Patient preferences were more closely related to questions assessing various aspects of familiarity with the procedure, than to race. Author suggests patients regardless of race may benefit from improved communication regarding proposed revascularization. Black patients were more likely to state they would opt for a procedure when surveyed by a black RA than a white RA. These difference ranged from 20% for PTCA if recommended, to 12% for having a CABG if it would improve survival, but they were not statistically significant.

EVIDENCE TABLE 4 VA-BASED STUDIES OF RACE AND QUALITY OF CARE FOR DIABETES

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race/ethnic groups compared | Characteristics of study pop | Source of race data | Type of outcome: describe | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Results, describe qualitatively | Comments
Halanych, 2006 | Racial/ethnic differences in diabetes care for older veterans: accounting for dual health system use changes conclusions. | To examine the extent to which accounting for non- VHA care changed conclusions about racial/ethnic disparities for VHA patients with diabetes | Cross-sectional observational study | 179,723 | 102 VHA facilities | Diabetic veterans who visited the VHA in FY98. Excluded: patients institutionalized for more than 6 months in FY98 - race/ethnicity other than white, black or hispanic - younger than 65 (not uniformly Medicare eligible) - patients whose primary VHA facility did not reliably transmit lab data to centralized databases, or facilities with low % lab data present (not credible) | Black, white, hispanic | 13.7% black (n=24,570) 83.0% white (n=149,222) 3.3% hispanic (n=5931) Diabetic veterans ≥ 65 y/o, mean age =72.4 | VHA inpatient & outpatient files (race/ethnicity is observer based) Medicare files | [underlined: Process measures]: Receipt of annual A1c, LDL, or dilated eye examination | National VA patient care database, VHA’s Health Care Analysis Information Group, pharmacy data, Medicare claims data | Bivariate analysis, multivariate logistic regression | patient characteristics (age, gender, income, education and comorbidity index), facility effects. | In VHA alone data (adjusted for patient characteristics), Hispanic and black patients were as likely as white patients to receive HbA1c testing (OR 1.06 [95% CI 0.99–1.13] and 1.04 [1.00–1.07]), and more likely to receive eye examinations (1.31 [1.24–1.38] and 1.33 [1.29–1.37] respectively). Hispanic patients were equally likely (1.01 [0.95–1.07]) and black patients were less likely (0.81 [0.79–0.84]) to receive LDL testing vs. white patients. In VHA plus Medicare data, Hispanic and black patients were less likely than white patients to receive HbA1c (0.76 [0.71–0.82] and 0.83 [0.80–0.87], respectively) and LDL testing (0.84 [0.79–0.90] and 0.70 [0.68–0.72] respectively), and equally likely to receive eye examination (0.91 [0.86–0.96] and 0.98 [0.95–1.01] respectively). Accounting for VHA facility had little effect on results. | Authors comments: limitations include 4% of the original cohort missing race/ethnicity data, there is no distinction between subpopulations within the 3 racial/ethnic groups. Racial/ethnic data was not self reported, but observer based in VHA administrative files. There is no mention to how this data was obtained from Medicare files. 25 VHA facilities were excluded from the cohort due to incomplete reporting of data to centralized VHA databases. Because of the exclusion of a predominately Hispanic facility, there were fewer Hispanic patients in the final cohort.
Heisler, 2003 | Racial disparities in diabetes care processes, outcomes, and treatment intensity. | To assess racial disparities in the equality of diabetes care processes, intermediate outcomes, and treatment intensity | Cross-sectional observational study | 916 | 21 VAMCs | Of an initial sample of 2000 veterans receiving diabetes care at one of 25 VAMCs in 4 VISNs, 80 eligible patients in each facility were randomly sampled. Patients were eligible if they had 2 outpatient visits in FY99, and one of the following - one hospitalization with a diabetes-related ICD-9 code - 2 or more outpatient visits with a diabetes-related ICD-9 code, or - at least 1 Rx for a glucose control medication or monitoring supplies Analysis was limited to respondents who identified themselves as black or white. | Black vs. white | 801 white patients 115 black patients | DQIP survey data, medical record information | [underlined: Process measures:] Receipt of an A1c, dilated eye examination and foot examination in the past year, LDL and nephropathy screen in the past 2 years [underlined: Outcome measures]: A1c level, LDL level and blood pressure | DQIP survey responses Medical record information was accessed for all survey respondents | Bivariate & multivariate analyses Multiple logistic regression | patient characteristics (age, education, income, insulin use, diabetes self- management, duration, severity, comorbidities, and health services utilization), facility effects, facility racial composition | Blacks were less likely to have LDL checked in the past 2 years (72% vs. 80%, p<0.05) and to have a dilated eye exam (50% vs. 63%, p<0.01). Racial disparities persisted after adjusting for patient characteristics. There were no racial differences in receipt of an A1c test or foot exam. After additional analysis allowing variation across facilities, there were no longer differences in receipt of eye exam. Black patients were more likely than whites to have poor cholesterol control (LDL ≥130) and blood pressure control (BP ≥140/90 mm HG) (p<0.01). There were no racial differences in the odds of having an elevated HbA1c (> 7.0). | Authors comments: cross-sectional analysis provides insufficient evidence for causality. The sample of black patients was relatively small, and may have lacked the power to detect racial differences on the measures for which no significant differences were found.
Walsh, 2002 | Unpacking cultural factors in adaptation to type 2 diabetes mellitus | To assess the use of a measure of ecocultural domains that is correlated with ethnicity in accounting for variance in adherence, quality of life, clinical outcomes and service utilization. (proposing a more reliable and interpretable approach to the measurement of factors likely to underlie ethnic differences in health services outcomes). | Cross-sectional observational study | 54 | Tucson VAMC | Eligible: Hispanic or non-Hispanic white veterans younger than 80 residing in Tucson, who were seen at the TVAMC between April 1,1996 and March 31, 1997. Must have ICD-9 of 250.xx (type 2 DM) Excluded: diagnosis of dementia or preliminary diagnosis of substance abuse | Hispanic vs. non-Hispanic white | Hispanic, n=26 non-Hispanic white, n=29 VA primary care patients with type 2 diabetes | self reported race/ethnicity was compared to ethnic label recorded in VISTA | Adherence to treatment (diet, exercise and medication), health-related quality of life, clinical indicators of disease management (HbA1c, fasting glc), and utilization of urgent and emergent services. | Standardized patient reports, VISTA (Veterans Health Informations Sytems and Technology Architecture), self administered questionnaire | Regression to provide an estimate of the bivariate and combined effect of independent variables (ethnicity, adaptation). | None | Patient adaptation (a summation of ecocultural domains) was correlated with ethnicity and accounted for more variance in all outcomes than did ethnicity. The unique variance accounted for by adaptation was small to moderate, whereas that accounted for by ethnicity was negligable. Higher adaptation scores are correlated with more positive outcomes (better adherence, higher QOL, better glycemic control, less utilization of urgent/emergent services). Hispanic veterans tended to have higher scores (0.28, SD=0.92) than non- Hispanic white veterans (−0.24, SD=1.02) t=2.01 (df=52, p=.05). | Authors comment: Adaptation can be seen as a more useful and more interpretable concept than ethnicity in explaining health and services outcomes. Because of the small sample size and lack of statistical power, α for statistical significance was set a 0.10 rather than 0.05.
Wendel, 2006 | Racial and ethnic disparities in the control of cardiovascular disease risk factors in Southwest American veterans with type 2 diabetes: the Diabetes Outcomes in Veterans Study | To examine the association between race/ethnicity and cardiovascular disease risk factor control in a large cohort of insulin-treated veterans with type 2 diabetes. | Cross-sectional observational study | 338 | 3 VAMCs in the American Southwest | Eligible: T2DM diagnosed after age 35, at least 1 daily injection of long- acting insulin, do not self-titrate insulin doses, diabetes medication regime had been relatively unchanged in the preceeding 2 months. Excluded: < 1 year expected survival, active alcoholism or substance abuse listed in medical record, history of diabetic ketoacidosis or type 1 diabetes, co-morbidities affecting glucose homeostasis | Hispanic (H), African American (AA), non-Hispanic white (NHW) | 338 veterans with insulin treated T2DM non-Hispanic white= 67% (n=226) Hispanic= 21% (n=72) African American= 10% (n=35) | self-report | The effect of race/ethnicity on glycemic control, insulin treatment intensity, lipid levels, and blood pressure control | Insulin=treated T2DM patients selected using electronic pharmacy databases. VA medical record and patient survey data used to determine outcomes. | Analysis of variance and multivariate linear regression | Depression scores, work hours per week, number of household dependents, employment status, age, baseline A1c, use of other hypoglycemic medication, BMI. | The mean hemoglobin A1c differed significantly by race/ethnicity: NHW 7.86 (1.4)%, H 8.16 (1.6)%, AA 8.84 (2.9)%, p = 0.05. Insulin doses (unit/day) also differed significantly: NHW 70.6 (48.8), H 58.4 (32.6), and AA 53.1 (36.2), p <0.01. Decrements in insulin doses were even greater among minority patients with poorly controlled diabetes (A1c ≥ 8%). Insulin-treated minority veterans, particularly AA, had poorer glycemic control and received lower doses of insulin than NHW. No significant racial/ethnic differences in lipid or blood pressure control were found. | The disparities in glycemic control and insulin treatment intensity could not be explained by differences in age, body mass index, oral hypoglycemic medications, socioeconomic barriers, attitudes about diabetes care, diabetes knowledge, depression, cognitive dysfunction, or social support. The research team was unable to assess whether minorities had fewer clinic visits, accounting for the difference in treatment intensity, or whether race/ethnicity has any effect on hypoglycemia (which is a major deterent to tight glycemic control).
Young, 2003 | Effects of ethnicity and nephropathy on lower-extremity amputation risk among diabetic veterans | To describe ethnic differences in the risk of amputation in diabetic patients with diabetic nephropathy. | Retrospective cohort | 429,918 | National VA database | All veterans with diabetes who received primary care within the U.S. VA Health Care System during FY98. (≥3 visits that year) | White, African American, Hispanic, Asian, Native American | Diabetic patients with and w/o renal disease; 2.6% women [underlined: Prevalent amputation (n=9.527]) mean age = 66.35 white = 63.1% (n=6,016) AfrAm = 25.1% (n=2,394) Hispanic = 9.2% (n=878) Asian = 0.1% (n=14) NativeAm = 0.8% (n=72) [underlined: Incident Amputation (n=3,289)] mean age = 66.0 white = 64.6% (n=2,126) AfrAm = 24.4% (n=804) Hispanic = 8.1% (n=267) Asian = 0.2% (n=6) NativeAm = 0.9% (n=30) | Administrative records: PTF and OPC | Risk of lower-extremity amputation in diabetic ethnic minority vs. whites (with and w/o renal disease) in a setting where access to and financial barriers to health care were comparable. | PTF - patient treatment files and OPC - outpatient clinic files | Cox proportional hazard modeling was used to estimate risk of amputation, modeled as a function of 2 covariates (ethnicity and presence of renal disease). | age, region, service-connected disability, CVD, HTN, COPD, region, presence of renal disease (multiple models done) | Veterans with amputations were in general older (66 vs. 64, p<0.001), more likely to be male (99.3%), more likely to belong to an ethnic minority group, and less likely to have service connection for their care at the VA compared to veterans without amputations. Native American veterans with diabetic nephropathy or diabetic ESRD had a 2.7-fold higher risk of amputation when compared with whites with diabetes and similar diagnoses of renal disease; African Americans = 1.4-fold higher risk, Hispanic = 1.2-fold higher risk. The presence of diabetic nephropathy increased the risk of amputation threefold in all groups. Asian veterans had a statistically sig. lower risk of amputation when models were adjusted for renal disease as well as age, region, service-connected disability, CVD, HTN and COPD. | Race dervied from administrative files. ~23% (n=92,048) subjects were reported as ethnicity “unknown”. Potential confounders such as duration of diabetes, type of diabetes, adequacy of glycemic control, risk factors known to affect onset and progression of diabetic nephropathy and ESRD, were not available and thus not included in this analysis.
Cramer, 2005 | The influence of insulin use on glycemic control: How well do adults follow prescriptions for insulin? | To determine the relationship between insulin self-management and glycemic control and to identify patient characteristics associated with better control. | Cross-sectional observation | 6,222 | 12 VAMCs (eastern US and Puerto Rico) in 2001 | Included: those patients receiving a Rx for any type of insulin or oral hypoglycemic agent (OHA) during July 2001 Excluded: patients who did not receive insulin during the 6 months prior to July 1, 2001(new insulin users) | Caucasian, African American, Hispanic/other, mixed/undefined (largely African-American mixed) | N = 6,222 patients with a Dx of diabetes who were chronic insulin users + or − an OHA 41% Caucasian 7% African American 30% Hispanic/other 22% mixed/undefined (largely African-American mixed) | VHA outpatient & inpatient database (administrative) | Compliance with prescribed insulin regimens using demographic variables, HbA1c levels, and a meaure of diabetes management intensity | VHA administrative data and VA Pharmacy benefits Management Rx database | Regression analysis | insulin use (compliance score and average HbA1c level by, age, sex and race compliance and treatment intensity | Caucasian and mixed/undefined patients had lower A1c levels than African-American or Hispanic/other patients African-American patients had lower levels of insulin use than all other patients (Caucasians had significantly higher insulin use than all other groups) African-Americans were half as likely as Caucasian patients to have higher insulin use as well as greater treatment intensity (using an approximate average based on the amount of insulin that is necessary to acheive glycemic control) | Authors note: Insulin use was less than prescribed across all groups but consistent with current and previous findings for OHAs, wherein most patient groups took approximately three-fourths of medication as prescribed, reflecting the good overall diabetes care, including patient education and communication with clinicians, in the VHA.
Safford, 2003 | Disparities in use of lipid-lowering medications among people with type 2 diabetes mellitus | To evaluate associations between use of lipid-lowering meedications (LLMs) and age, ethnicity, sex, marital status, Charlson Index, heart disease ICD-9 codes, orak agents and insulin, hospitilization status, and LDL cholesterol levels. | Cross-sectional observation (2 samples; 1 for FY98, 1 for FY99) | 97,690 (FY98), 198,991 (FY99) | VHA facilities nationwide | Veterans with diabetes (HEDIS administrative criteria for diabetes: ≥2 face-to-face contacts with a physician in an outpatient facility and an ICD-9-CM code 250.xx; or ≥1 inpatient stay and ICD-9-CM code 250.xx; or ≥1 Rx for insulin or an oral hypoglycemic agent) who received care at VHA in FY98 or FY99 and has at least 1 LDL-C value available | White, African American, Other, Unknown | White = 58,216 (FY98), 117,625 (FY99) African Amer = 14,841 (FY98), 28,649 (FY99), Other = 6355 (FY98), 11,374 (FY99), Unknown = 18,278 (FY98), 41,343 (FY99) | VHA outpatient database (administrative) | The extent to which utilization of LLMs differed by coronary disease status, age, sex and race. | inpatient and outpatient records from central VHA database and Healthcare Analysis Information Group Diabetes Project (Milwaukie, Wis) | Bivariate analysis and logistic regression | age, sex, marital status, heart disease status, hospitalization within a VHA facility in the fiscal year, categorized modified Charlson score, LDL-C values, and diabetes treatment group. | In FY99, African Americans were 0.75 times (CI, 0.73–0.77) less likely than whites (similar in FY98) and minorities who were neither African American nor white were 0.83 times less likely than whites (0.77 times less likely in FY98), to receive LLMs. | LLMs included statins, fibrates, resins, and niacin. Authors Note: achieving best practices is an attainable goal in the VHA (though it is not being met) ince effective, largely well-toerated agents that can achieve very low LDL-C are available at no or minimal copay to veterans. Largest discrepancy was in diabetics without coded heart disease.

EVIDENCE TABLE 5 VA-BASED STUDIES OF RACE AND QUALITY OF CARE FOR HIV AND HCV

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race/ethnic groups compared | Source of race data | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Characteristics of study pop | Results, describe qualitatively | Comments
Bennett, 1995 | Racial differences in care among hospitalized patients with Pneumocystis carinii pneumonia in Chicago, New York, Los Angeles, Miami, and Raleigh-Durham | To determine if there were racial variations in diagnostic and therapeutic care for HIV-infected individuals with PCP. | Retrospective chart review | 627 VA patients | 14 VA hospitals in 5 cities. | The target sample size for each city was 150 from VA hospitals. To be included, patients had to 1) have received medical care at the study hospital between 1987–1990, 2) have confirmed PCP, and 3) have been 18+ old. Patients were excluded if they had received inpatient care for the current PCP episode at another hospital, had a cardiac arrest prior to admission, or were admitted only for a diagnostic bronchoscopy. | Black, Hispanic, or white | Medical record abstraction | Medical record abstraction | Multivariate logistic regression | For effect of race/ethnicity on patterns of care or outcome: race and ethnicity, insurance status, age, sex, risk group status, severity of PCP illness at admission, use of zidovudine or PCp prophylaxis in the 30 days prior to admission, hospital ownership, teaching affiliation, and volume of patients with AIDS. | 41% black 16% Hispanic 43% white Mean age: 40.1 black, 41.1 Hispanic, 43.5 white IVDU 43.8% black, 50% Hispanic, 16% white (p<0.01) | There were no significant racial variations in the diagnostic patterns of care - namely length of hospitalization, use of bronchoscopy within 2 days of admission, use of anti-PCP medication initiation within 2 days of admission - or in the proportion who died in the hospital. (Detailed results in article, Table 3) | No disparities in in-hospital mortality rates, use and timing of a bronchoscopy, or receipt of timely anti-PCP medications.
Cheung, 2005 | Chronic hepatitis C in Latinos: natural history, treatment eligibility, acceptance, and outcomes | To investigate whether there were differences in the natural history, treatment eligibility, and treatment outcomes between Latinos and Caucasians with chronic hepatitis C infection. | Multicenter 2-phase prospective study: 1) screening, 2) treatment | 2510 whites and 421 Hispanics enrolled, of whom 481 whites and 88 were treated | 24 VAMCs throughout US | Patients were recruited from the specialty clinics of 24 VAMCs throughout the US between 1999–2000. All had a positive anti-HCV test, were documented as viremic by RNA-PCR, and considered for treatment with interferon alpha-2b and ribavirin. Phase 1 (screening) evaluated the epidemiology of HCV infection and treatment candidacy among US veterans. Phase 2 (treatment) included all subjects who were treated with interferon alpha-2b and ribavirin. Patients were eligible for Tx if they were HCV-Tx naive, had compensated liver disease, had normal values of serum creatinine, and met pre-defined lab parameters; or if the treating clinician considered the patient a candidate independent of VA guidelines. | Hispanic v. white | Self-report | Patients completed a questionnaire by study staff. Lab values obtained from medical records. | Univariate analysis for treatment decision; Multivariate logistic regression for early discontinuation and SVR. | Multivariate logistic regression for early discontinuation and SVR adjusted for ethnicity, genotype, viral load, and AFP. | HCV infected. Mean age 50 97.2% male 14.4 % Hispanic 85.6% white HIV coinfection: 20.4% of Hispanics 3.9% of whites | More Hispanics than whites met all VA treatment eligibility criteria (49.8% v 39.6%, p=0.0001) or were considered a treatment candidate by physician assessment (43% v 37.8%, p=0.046). There was no racial difference in the percentage who actually initiated treatment (20.9% of Hispanics v 19.2% of whites). Hispanics were more likely to discontinue treatment early either due to side effects or dropout: 39.7% v 28.9%, p=0.043. This association persisted in multivariate analysis. Ethnicity was not significantly associated with lower sustained virological response, though Hispanics tended to have lower SVR rates than whites: 14.8% v 22.5%, p=0.10. | Proportionally more Hispanics than whites were eligible for treatment, but equal proportions actually received treatment. Hispanics discontinued treatment more often, and tended to have lower sustained virological response rates (SVR does not necessarily reflect the quality of care received).
Korthuis, 2004 | Lipid screening in HIV-infected veterans | To assess adherence to lipid-screening guidelines in a retrospective cohort of HIV-infected US veterans cared for at sites throughout the US & Puerto Rico, as part of a larger effort to evaluate and improve HIV clinical practice under the auspices of the Quality Enhancement Research Initiative for HIV (QUERI-HIV) program. We hypothesized that lipid screening would depend on predisposing patient characteristics (age, gender, HIV exposure group, and race/ethnicity), medical need, and enabling characteristics. | retrospective cohort study | 4065 | National VA database | All HIV-infected patients aged 19+ who received protease inhibitors for at least 6 consecutive months between 1999–2001. All VA facilities that treated at least 1 HIV-infected patient were included in the analysis. | Black, Hispanic, or white | Administrative data: VA ICR | Veterans Administration Immunology Case Registry (VA ICR) | logistic regression models to predict likelihood of receiving a lipid-screening test by 6 months | Age, gender, type of HIV exposure, race, AIDS status, CVD, diabetes, hyperlipidemia, hypertension, smoking, urgan location, presence of HIV case management, HIV QI program implementation, HIV practice guidelines present, and region | Mean age 46.8 99% male 36% black 9% Hispanic 4% other 50% white 42% AIDS 12% Hx of hyperlipidemia | There were no significant racial differences in likelihood of lipid screening within 6 consecutive months after initiating PI treatment, in 3 models of various levels adjustment for confounders.
McGinnis, 2003 | Understanding racial disparities in HIV using data from the veterans aging cohort 3-site study and VA administrative data | 1) To examine racial differences in survival among HIV+ veterans, and 2) to use in-depth clinical data from VACS 3 to explore explanations for racial disparities in survival by examining health status at study entry, use of clinic services, clinical management, and adherence to HIV meds. | Prospective cohort study (VACS 3) | 865, VACS data | VACS3 study at 3 VAMCs in TX, OH, NY | For survival analysis: HIV+ veterans aged 25–84 who received a first HIV diagnosis between 1999–2001. 1595 (20%) of 7425 HIV+ veterans were of unknown race and were excluded. Included veterans categorized as white, black, Hispanic white, and Hispanic black (combined into 1 Hispanic group). Excluded veterans who were first identified as HIV+ and died on the same day. For VACS 3: HIV+ veterans from infectious-disease clinics at 3 VAMCs in TX, Oh, and NY. | Black, Hispanic, or white | For survival analysis: administrative data: National Patient Care Database For VACS 3: patient’s race and gender were collected on the provider survey. | For Survival: administrative data: inpatient and outpatient treatment files. VACS3 baseline survey data was collected from patients and their providers 1999–2000, and followup data were collected approx 1 year after enrollment. Lab and PBM data used to determine clinical management and PCP prophylaxis. | Cox proportional hazards model for survival by race; VACS 3 bivariate data analyzed by chi square tests | Survival analysis adjusted for age. Bivariate (chi2) analysis of VACS3 were unadjusted. | VACS data: Median age 50 (range 29–79) 54.2% black 33.8% white 12% Hispanic | Survival: In the national data, blacks and Hispanics had significantly higher mortality rates than whites controlling for age: HR 1.41, 95% CI 1.19–1.66 among blacks, HR 1.41, 95% CI 1.06–1.86 for Hispanics. Mortality did not significantly differ between blacks and Hispanics. Mortality rates by race were similar between VACS 3 and the national data. Health status: providers estimated that 28% of whites had a 90–100% chance of being alive in 5 years, compared with 22% of blacks and 14% of Hispanics (p=0.008). 41% of Hispanics had a low CD4 compared with 24% of whites and 28% of blacks (p=0.004). Viral load did not differ by race. Health care use: Among those on HAART, proportionally more blacks and Hispanics had 2 or more VA clinics within the last 6 months, compared with whites. Clinical management: no racial differences between % on HAART; no racial differences in proportions of patients with 4+ CD4 and viral load lab test in past year. Among vets with low CD4, no racial differences in proportions on PCP prophylaxis. Adherence to HIV meds: No racial differences on all 3 patient-reported adherence measures. | Better survival and prognosis by provider among whites compared with blacks and Hispanics. There were no racial differences in clinical management indicators or adherence to HIV medications.
Singh, 1996 | Determinants of compliance with antiretroviral therapy in patients with human immunodeficiency virus: prospective assessment with implications for enhancing compliance | To determine the prevalence of treatment non-adherence among HIV patients, to assess sociodemograhic, psychobehavioral, and illness variables that influence compliance and to assess change in compliance over time. | Prospective cohort study | 52 | Pittsburgh VAMC | All new patients admitted or seen as outpatients with HIV infection were eligible for the study. Excluded patients considered to be at imminent death upon initial interview. | Black v. white | Self-report. Patients were interviewed about demographics, living arrangements, education, employment, and social and religious support. | Psychological indices as well as physical functioning and medical status indicators were assessed at baseline and every 6 months. Compliance was assessed by pharmacy refill records. For patients with uninterrupted refill record, zidovudine use was assessed by macrocytosis: an increase of MCV >100 fL indicated zidovudine consumption. | Logistic regression to evaluate factors associated with non- compliance. | Socioeconomic model included employment, race, social support, and prior IVDU. Another model included opportunistic infection, POMS score >42, IVDU, and race. | Mean age 40 (range 23–68) 33% black 2% Hispanic 65% white | 71% (22/31) of white patients were compliant, compared with 46% (7/15) of black patients (p=0.10) In a model that adjusted for Profile of Mood States score >42 and absence of prior opportunistic infection, and prior IVD use, black race was significantly predictive of non-compliance compared with whites: OR 1.4, 95% CI 1.1–1.8 (p=0.02). | Author concludes: compliance was lower in black patients with HIV, independent of IVD use, education, social support, employment, history of opportunistic infections, and depression. Note: small sample size
Kemppain en, 2001 | HAART adherence in culturally diverse patients with HIV/AIDS: a study of male patients from a Veteran’s Administration Hospital in northern California | To examine factors associated with HAART adherence and the extent to which factors varied across age, ethnicity, and IVD use. | Cross-sectional survey | 46 outpatients 6 health care providers | 1 VA hospital in SF Bay Area | 46 outpatients receiving their care at an HIV/AIDS clinic in a VA hospital in SF Bay Area. | Non-white v. white | Self-report | Critical incident technique, an intensive method of interview. Patients were asked to list current antiretroviral meds, to recall specific incidents that affected their adherence to HIV meds. Health care providers were asked to describe specific things that helped or hindered patients in taking meds. | Interviews analyzed through inductive classification; Ethnograph | None | 100% male Mean age 49.8 30.4% black 50% prior or current IVDU | Nonwhite patients were significantly (p<0.048) less likely than white patients to report incidents that related planning to medication adherence. Nonwhite patients were more likely than white patients to report incidents that reflected the absence of an established medication plan. Positive and supportive relationships with others were significantly associated with increased medication adherence among non-whites (p<0.005). Author comments that these findings emphasize the key role that supportive relationships with health care providers, family, and friends play in affecting increased medication adherence. There were no racial differences in 4 major adherence categories: 1) use of reminders and cues; 2) response to HIV/AIDS; 3) characteristics of medications; 4) patient characteristics. | Author’s comments place emphasis on the importance of support services aimed at facilitating adherence particularly among nonwhites.
Butt, 2006 | Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects | To quantify the rates of treatment prescription and the effect of comorbidities on hepatitis C virus treatment rates in HCV- HIV coinfected veterans | Retrospective study of national VA data | 6502 | National VA database | Sample of HIV-HCV coinfected subjects was assembled from the VA National Patient Care Database (NPCD) and the VA Pharmacy Benefits Management (PBM) database. Included all subjects seen in the VA healthcare system between 1999–2003. | Black, Hispanic, white, other/unknown | Administrative data: NPCD | NPCD and PBM databases. Prescription for HCV defined as interferon-alpa, pegylated interferon-alpha, or a combination of either with ribavirin for any duration of time. | Multivariate logistic regression | Age, race, gender, alcohol use, drug use, anemia, hepatitis B, cirrhosis, diabetes, coronary artery disease, stroke, pulmonary disease, bipolar disorder, major depression, schizophrenia, post-traumatic stress disorder, peripheral vascular disease, hypertension, year of diagnosis | HIV-HCV coinfected Mean age 48 98.2% male 50.3% black 9.8% Hispanic 24.1% white 15.8% other/unk | Of 6502 HCV-HIV coinfected subjects, 469 (7%) were prescribed treatment for HCV. The non-treated subjects were older (mean age 48.6 v 47.7 yrs, p=0.007) and more likely to be black (52% v. 32%, p<0.0001). In multivariate analysis, non-white ethnicity was a predictor of non-treatment for HIV: OR (95% CI) for black race was 0,45 (0.35–0.57), for Hispanic race 0.56 (0.38–0.82) compared with whites. Other predictors of non-treatment were increasing age, drug use, anemia, bipolar disorder, major depression, and mild depression. | Non-white race was associated with a lower likelihood of receiving treatment for HCV. Blacks were 55% less likely, and Hispanics 44% less likely, to be prescribed treatment after adjusting for comorbidities and drug and alcohol use.
Butt, 2006 | Rate and predictors of treatment prescription for hepatitis C | To determine the rates of HCV treatment prescription in US veterans diagnosed to have HCV, and to determine the role of demographic characteristics and medical and psychiatric comorbidity upon the rates of treatment. | Retrospective study of national VA data | 113,927 | National VA database | Included patients with HCV in NPCD and PBM databases who received care in any VA facility between 1999–2003. Excluded subjects with a diagnosis of HIV infection. | Black, Hispanic, white, other/unknown | Administrative data: NPCD | NPCD and PBM databases. Prescription for HCV defined as interferon-alpha, pegylated interferon-alpha, or a combination of either with ribavirin for any duration of time. | Multivariate logistic regression | Race, gender, alcohol abuse/dependence, drug abuse/dependence, anemia, hepatitis B, cirrhosis, diabetes, coronary artery disease, stroke, pulmonary disease, bipolar disorder, major depression, mild depression, schizophrenia, post trumatic stress disorder. | HCV monoinfection Mean age 51.1 96.9% male 22% black 5.2% Hispanic 40.1% white 32.7% other/unk | In a multivariable logistic regression model, Black race (OR 0.64, 95% CI 0.60–0.68) and Hispanic race (OR 0.88, 95% CI 0.80–0.96) were predictors of non- treatment for HCV compared with whites. Other predictors were increasing age, alcohol abuse, drug abuse, anemia, hepatitis B infection, coronary artery disease, stroke, bipolar disorder, major depression, mild depression, and schizophrenia. Liver cirrhosis and diabetes were associated with a higher likelihood of treatment prescription for HCV. | Non-white race was associated with a lower likelihood of receiving treatment for HCV. Blacks were 34% less likely, and Hispanics 12% less likely, to be prescribed treatment after adjusting for comorbidities and drug and alcohol use. Author notes: our study does not take into account eligibility for HCV treatment. About 15–25% of HCV infected persons clear the viremia spontaneously and are not candidates for treatment. Others have minimal evidence of liver disease from HCV and may reasonably decide to forego or defer treatment.

EVIDENCE TABLE 6 VA-BASED STUDIES OF RACE AND QUALITY OF CARE FOR MENTAL HEALTH AND SUBSTANCE ABUSE

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race groups compared | Characteristics of study pop | Source of race data | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Results, describe qualitatively | Comments
Akpaffiong, 1999 | Cross-cultural differences in demented geropsychiatric inpatients with behavioral disturbances | To determine racial differences in treatment of behavioral disturbances in elderly demented patients | Prospective cohort study | 197 | Inpatient geropsych ward | All patients with a diagnosis of dementia admitted to a geropsych unit for behavioral disturbance defined by physical aggression verbal theats or genearl confusion)/Excluded if not Black or not White, patients with delerium. | Blacks and Whites | Elderly demented veterans inpatients with behavioral disturbances | Physician assessment | Various standardized clinical interviews and scales | t-testing | none | Found no differences in symptomatology on admission, in medications prescribed or symptoms on discharge. | The study did not perform adjustment for covatiates. The study is likely a negative study because there was no variation in evaluation or treatment. The use of standardized interviews and scales and standardized treatments based on previously determined criteria as well as the fact all patients were taken care of at the same VAMC by the same subspecialists severely limited variation in the independent variables.
Becerra, 1981 | The mental health-seeking behavior of Hispanic veterans | To describe the mental health seeking behaviors of Hispanic veterans. | Cross Sectional analysis, survey methodology | 529 | Community | Randomly selected Hispanic users of one of four different VAMCs. Unclear what if any additional inclusion/exclusion criteria existed. | Hispanics and non- Hispanics | Veterans using one of four different VAMCs. | Self-Report | Answers to questionnaire items | none | none | Found similar need for mental health in Hispanics and Non-Hispanics | This is purely a descriptive study without considerable statistical analysis.
Blow, 2004 | Ethnicity and diagnostic patterns in veterans with psychoses | To determine if race is a predictor in the diagnosis of schizophrenia and schizoaffective disorder rather than bipolar disorder | Cross Sectional analysis. | 134523 | National VA database | All patients within the National Psychosis Resgistry diagnosed with schizophrenia, schizoaffective disorder or bipolar disorder within fiscal year 1999. | Whites, Blacks and Hispanics | Veterans with bipolar, schizophrenia or schizoaffective disorder within the National psychosis registry | Administrative record | National registry | Chi square testing, multivariate regression | None | Blacks and Hispanics had a higher odds of diagnosis with schizophrenia rather than bipolar disorder compared to Whites. The also had a higher odds of diagnosis with schizoaffective disorder. | The authors suggest the increased rates of dual diagnosis in Blacks may indicate increased hallucinations lower functionality due to substance abuse and may increase the likelyhood of being diagnosed with schizophrenia and schizoaffective disorder. They suggest further research in this area. They also suggest further research to identify physician and system factors which may lead to these disparities.
Booth, 1992 | Age and ethnicity among hospitalized alcoholics: a nationwide study | To examine an association between race, age and other sociodemographic factors and completing inpatient treatment for alcohol detoxification. | Cross Sectional analysis. | 62,829 | National VA database: looking at inpatient setting | Male admitted to VAMC with a primary or secondary diagnosis of alcohol dependence. Not in remission and does not have a primary diagnosis of drug dependence. | African Americans, Caucasions, Hispanics, Native Americans | Male veterans with diagnosis of alcohol dependence admitted to a VAMC during fiscal year 1987 | Administrative record | Administrative data defining completed treatment as length of stay within 10% of the modal LOS for the particular VAMC’s alcohol treatment program. ~25 days for complete treatment 1–5 days for partial treatment. 0 days for no treatment. Excluded >6 days but less than within 10% of modal LOS. | Chi-Square tests. No regression | None | Found that African Americans and Hispanics had lowest association with completion of treatment. Highest association with no treatment. Native Americans had highest association with completion of treatment. | First generation study. Study finds statistical association between race and treatment outcome. No adjustment for sociodemographic variables or clinic location.
Bosworth, 2000 | Racial variation in wanting and obtaining mental health services among women veterans in a primary care clinic | To examine the association between race and desire for mental health services and race and receipt of mental health serviecs among Women veterans. | Prospective cohort study | 526 | Outpatient | Women, between ages of 20–49 inclusive, first visit to the Women’s Veterans Comprehensive Health Clinic in Durham NC between 1/1/94 and 12/31/96. Excluded if did not self-report there race and excluded if referred from an outside clinic. | Blacks and Whites | Women veterans at their first clinic visit. | Self-Report | Use of a questionnaire and administrative data. | logistic regression | age, marital status, education, symptoms of depression and eating disorder. | The study found that Blacks women were more likely to desire mental health services and equally as likely to receive mental health services. | No recommendations for further research are suggested.
Greenberg, 2003 | Change in mental health service delivery among blacks, whites, and Hispanics in the Department of Veterans Affairs | To determine if race is associated with mental health service delivery and how these assocations change over time when a health delivery system switches to a managed care model. | Retrospective cohort study | 184,999 | Inpatient and outpatient care | White, Black or Hispanic veterans discharged from inpatient psych or substance abuse wards during the first have of 1995 1997 1999 and 2001. Excluded patients for which there was not complete administrative data. Also excluded veterans who were classified as both Black and Hispanics. | White, Black and Hispanic | Recently discharged veterans who had been admitted with psychiatric or substance abuse disorder. | Administrative record | Administrative data | Generalized equation modeling | age, sex, marital status, income, receipt of VA benefits, psychiatric diagnoses, medical diagnoses, distance from patient residence to VA. | Mixed results indicating that overall Blacks had worse quality of inpatient care measures and worse continuity of care measures than Whites. Hispanics had worse quality of inpatient care measures compared to Whites. When examining trends over time, Blacks had more improvements in most outcomes compared to Whites. Hispanics had worsening of continuity of care measures compared to Whites over time. | The authors suggest further study to examine the mechanism by which Hispanic veterans have worsening continuity of care measures compared to Whites over time. The authors suggest the move to a managed care model may result in fewer minority physicians and development of perceived barriers among Hispanic veterans may play a role and are a potential area for further research.
Greenberg, 2004 | Changes in satisfaction with mental health services among blacks, whites, and Hispanics in the Department of Veterans Affairs | To determine if minority veterans’ satisfaction with mental health care from recent inpatient stays changed during a period of major systems change in the department of veterans affairs. | Retrospective cohort study | 16,223 | Inpatient | All veterans admitted to psychiatric wards who responded to post hospitalization satisfaction survey sent ~4mons after discharge/Excluded if not White or not Black or not Hispanic | Whites, Blacks and Hispanics | Redently discharged veterans admitted for mental health care. | Administrative record | Questionnaires | Linear regression with hierarchichal linear modeling | age, sex, income marital status, distance of residence from nearest VA, compenstation status, psychiatric diagnoses, medical comorbidity, hospital size, inpatient mental health expenditures and academic influence | Levels of satisfaction among Blacks were significantly higher on most measures compared to Whites. Hispanics also had satisfaction levels significantly higher than that of Whites, but not as many measures as Blacks. Over time there one out of sixteen measures of satisfaction fell significantly for Blacks compared to Whites while two of the measures of satisfaction rose significantly for Blacks compared to Whites. There were no changes in satisfaction of Hispanics compared to Whites over time. | This authors of this study suggest that minorities were not disadvantaged from systems changes over time. While satisfaction may be similar across groups, it certainly does not indicate that the quality of care was similar. It may be that minorities consciously or unconsciously have lower expectations for mental health care and thus are satisfied with lesser quality. (the authors acknowledge this) One limitation of the study is that only 37% of vets responded to the survey suggesting that selection bias of high or low satisfied vets were more likely to respond.
Grubaugh, 2006 | Racial differences in psychiatric symptom patterns and service use in VA primary care clinics | To examine racial differences in psychopathology and mental health service use between Whites and Blacks | Cross Sectional Analysis | 713 | Outpatient | Veterans using psychiatric clinics at one of four southern VAMCs during fiscal year 1999 who consented to participation and responded to a follow-up questionnaire/Excluded vets without complete data on questionnaires and those who were not Black or not White. | Whites and Blacks | Southern veterans with psychiatric illness, predominantly PTSD | Self-Report | Questionnaires and chart review were used to measure disease prevalence and severity. Administrative records were used to measure health utilization | chi square, t-tests, analysis of variance, analysis of covariance | age | Blacks were more likely to have substance dependency and use substance abuse treatment centers. They were also more likely to use urgent care and primary care visits. Whites were more likely to have a childhood history of sexual abuse and a history of trauma. | Authors suggest future studies validate their findings.
Kales, 2000 | Race and inpatient psychiatric diagnoses among elderly veterans | To determine associations between race and psychiatric diagnoses among elderly inpatients. | Cross Sectional analysis. | 23758 | National VA patient treatment file database | Veterans 60 years old or older hospitalized during fiscal year 1994 for psychiatric diagnosis. Non-Black, non-White, non-Hispanic patients were excluded. | Blacks, Whites and Hispanics | Elderly veterans admitted for psychiatric diagnoses. | Administrative record | National database | Chi square tests, analysis of variance and configural frequency analysis | Stratified by age and treatment setting | Blacks were found to be diagnosed with mood disorders significantly less than expected. Blacks and Whites over 70 were diagnosed with cognitive disorders significantly more often than expected. | Authors suggest studies to explore patient presentations and symptoms, physician bias and misdiagnosis as potential causes for differences in diagnostic prevalences. Authors suggest studies to examine increasing religious services to those who use religious coping as psychotherapy.
Kales, 2000 | Race, psychiatric diagnosis, and mental health care utilization in older patients | To examine mental health utilization among elderly veterans stratified by psychiatric diagnosis. | Retrospective cohort study | 23,718 | National database: Outpatient, post discharge | All veterans 60 years or older admitted with an psychiatric ICD-9 code as primary diagnosis during fiscal year 1994./Excluded non-White, non-Black or non-Hispanic patients | Whties Blacks and Hispancis | Elderly veterans admitted for psychiatric diagnoses. | Administrative record | National database, Readmission defined as admission for mental health care with two years of the index hospitalization. Outpatient visits included all mental health outpatient visites within two years of the index hospitalization. | chi square, analysis of variance, multivariate analysis of variance and analysis of covariance. | age, medical comorbidity, psychiatric comorbidity and survival months | Whites with substance abuse were more likely than Blacks or Hispanics to be readmitted within two years. Blacks with substance abuse admissions had more outpatient visits than Whites, but not Hispanics. Blacks with psychotic disorder admssions had fewer outpatient visits than Whites but not Hispanics. | The authors imply that misdiagnosis and physician bias may be responsible for the decreased outpatient visits in Blacks and could warrant further study.
Kilbourne, 2005 | Racial differences in the treatment of veterans with bipolar disorder. | To determine racial differences in guideline concordant care for patients with bipolar disorder. | Retrospective cohort study. | 2316 | Inpatient and outpatient care | All White or Black veterans within VISN-4 (mid-Atlantic region) with either one ICD-9 code for bipolar disorder generated as an inpatient or two separate ICD-9 codes generated at different times during an outpatient during fiscal year 2001. Patients who died during follow-up or did not have complete demographic data in the database were excluded. | Blacks and Whites | Newly diagnosed White or Black veterans with bipolar disorder. | Administrative record | Administrative record | Chi square analysis and multivariate logistic regression | age, gender, marital status, co-morbid illness and substance abuse status. | Blacks were significantly less likely to have adequate outpatient follow-up after diagnosis after full adjustment. No statistically significant differences were noted among the other outcomes. | First generational study; the authors suggest examining patient, provider and system level factors which may cause the disparities found.
Kilbourne, 2005 | Clinical, psychosocial, and treatment differences in minority patients with bipolar disorder | To determine if racial differences in clinical, psychosocial and treatment among veterans admitted with bipolar disorder. | Cross Sectional analysis. | 330 | Inpatient psychiatric wards | All veterans admitted to inpatient psychiatric wards between Jan 1, 1997 and Dec 31, 2000 as a part of VA Cooperative Study #430 with a diagnosis of bipolar I or II and an episode of mania or major depression at the index hospitalization. Excluded those with a MMSE<26, patients with ongoing detox, terminally ill patients and patients already enrolled in other studies. | Native American, Asian Pacific Islander, Black, Hispanic, White and other. | Veterans admitted to inpatient psych wards for bipolar disorder with ongoing mania or major depression. | Self-Report | Questionnaires including the Structured Clinical Interview for DSM-IV as well as items pertaining to the other outcomes. | Chi square analysis, t-tests and multiple logistic regression. | Age, gender and previously mentioned clinical, psychosocial and treatment outcome variables noted in “Type of outcome: describe” | Blacks were significantly more likely to be associated with a diagnosis of cocaine substance abuse than Whites or other minorities. This association remained after full adjustment. Other minorities were significantly more likely to be involunatirly committed. | It should be noted that there was a large decline in participation rate among the eligible veterans 330/1131 and that participation/non-participation was differentially associated with race making the results of this study less generalizable. The authors suggest targeted interventions for Blacks and other minorities considering enhancing existing treatment programs with substance abuse treatment.
Kilbourne, 2006 | Patterns of psychotropic medication use by race among veterans with bipolar disorder | To determine if race is associated with patterns of medication use differences for bipolar disorder. | Retrospective Cohort | 2958 | National VA database. | All patients with a diagnosis of bipolar disorder given during fiscal year 2001 within the VISN-IV VA health care system/Limited to either one inpatient diagnosis or two outpatient diagnoses and excluded patients with unknown race. | Blacks and non-Blacks | Veterans with bipolar disorder who used VA health care services in FY 2001. | Administrative record | Administrative record | multivariate regression | gender, age, marital status, coypament waiver eligibility, number of medical comorbidities, bipolar subtype, and whether bipolar was diagnosed as an inpatient vs. outpatient. | Blacks were significantly less likely to receive lithium or SSRIs compared to non-Blacks and were significantly more likely than non-blacks to receive first generation anti-psychotics and any antipsychotics. | It should be noted that the authors did not control for disease severity or disease presentation. The authors suggest physicians may be less likely to prescribe lithium because previous evidence has suggested blacks have worse side-effect profiles with lithium and hence anti-psychotics are used and first generation anti-psychotics are used because cost better and compliance is easier than second generation anti-psychotics. These serve as future research questions.
Koenig, 1992 | Religious coping and depression among elderly, hospitalized medically ill men | To examine the relationship between religious coping behavior and depression. | Cross Sectional longitudinal analysis. | 850 | Inpatient medical/neurological wards at Durham NC VAMC | Males 65 years or older admitted to medical or neurological wards between Sept 1, 1987 and Jan 1 1989./Psychiatric patients and patients with MMSE<15 | Blacks & Whites | Elderly veterans admitted to Durham VAMC for medical or neurological illness. | Self-Report | Depressive symptoms were measured in two ways. The Geriatric Depression Scale and Hamilton Rating Scale for Depression. | Pearson correlations and step wise regression | Age, race, occupational status, religious affiliation, social and economic support/resources, physical and mental health. | Blacks race and religious coping behavior was significantly correlated, r=0.15 p<0.001. Black race appears to be inversely correlated with depression. Also following regression, religious coping behavior was significantly inversely correlated with depressive symptoms (r=−0.14 Geriatric scale, r=−0.19 Hamilton scale both p<0.001) | The measure of effect size was the pearson correlation r. The size of the sample and degree of variation in the sample allowed for relatively small correlations to yield statistical significance.
Leda, 1995 | Race in the treatment of homeless mentally ill veterans | To examine homeless veterans with psychiatric illness and substance dependency for racial differences in outcomes following treatment in the Domiciliary Care for Homeless Veterans program | Cross Sectional analysis | 263 | Inpatient/Outpatient | Veterans with their first admission to the Domiciliary Care for Homeless Veterans program at the VAMC in Palo Atlo, Cleveland or Pines, Florida between Oct 1988 and July 1989./Included only Whites and Blacks | Whites and Blacks | Homeless veterans suffering from pscyhiatric and or substance abuse disorders. | Administrative record | Mental health service use measured using patient recall of outpatient visits and hospital admissions. Improvement measured using questionnaires with items regarding suicide attempts, violent behavior, social functioning and the Addiction Severity Index. | chi square analysis, analysis of variance and analysis of covariance | none | Blacks showed significantly more improvement in medical illness and violent behavior. Blacks had significantly more suicide attempts and Whites had significantly more outpatient visits and attendance of AA/NA meetings. | This was a descriptive study without rigorous statistical analysis.
Murdoch, 2003 | Racial disparities in VA service connection for posttraumatic stress disorder disability | To determine if racial disparities exist in the granting of Service Connection for PTSD. | Retrospective cohort study using mailed survey method. | 3337 | Used national database to select random sample veterans claiming of PTSD disability | Any male or women veteran who applied for service connection on the basis of PTSD disability between Jan 1994 and Dec 1998/Excluded duplicate records, records of deceased and veterans without known addresses. | Native American, Asian, Black, Hispanic, Pacific Islander and White. | Random sample of all veterans who applied for service connection due to PTSD disability. | Self-Report | Abstraction from VA database | Chi square, Mantel- Haenszel’s method analysis of covariance and step-wise regression. All with bonferroni corrections for multiple comparisons. | age, race, sex, period of service, branch of service, VISN, time since application, intervention status, PTSD symptom severity, social role functioning, physical functioning, work-role, post-service hardships, Charlson Co-morbidity scores, combat exposure scores and in- service sexual assault status, | Blacks were less likely to be granted disability on the basis of PTSD when compared to whites. These differences persisted following full adjustment 43% (Bkacks) vs. 45% (non-blacks) and remained statistically significant. Granting service connection for illnesses other than PTSD was similar between Blacks and veterans of other races. | One problem with the study is the time delay between filing a claim for disability and measuring disease severity. Sometimes 4 years had passed, making it a possibility that differential worsening of PTSD symptoms over time might explain differences in outcomes. The authors found an association between race and the likelyhood of being diagnosed with PTSD after a claim was filed by the veteran, with Blacks being less likely. This may be due the association between race and claims developers requiring further sources of corroboration of sexual traumas for Black veterans. These association did not reach statistical significance, however, may explain why differences in receiving service connection exist. The authors suggest studies to examine why these apparant associations between race and diagnosis of PTSD exist in the VA health care system.
Owen, 2001 | Variations in prescribing practices for novel antipsychotic medications among Veterans Affairs hospitals | To determine variation in prescriptions of novel anti- psychotics among VAMCs and to determine if socioeconomic factors are associated with novel anti-psychotic prescription. | Retrospective cohort study. | 13 sites, 599 patients | Discharge post inpatient treatment | VAMC sites were selected if atleast 125 patients had been discharged in 1997, the mental health clinicians were interested in participating and there existed a second VAMC within the same VISN which met the first two criteria. | Whites and Non-whites defined as Blacks, Hispanics, Asian, Pacific Islander or other. | Recently discharged veterans who had been admitted with a primary diagnosis of schizophrenia. | Administrative record | Exctracting data indicating prescription for a novel anti-psychotic was made with 7 days prior to discharge up until 90 days after discharge. | Chi square testing, analysis of variance and logistic regression. | none | Whites were significantly more likely to receive prescriptions for novel anti- psychotics compared to non-Whties | There was no adjustment for confounders, particularly variations in prescribing practices across sites and disease severity. The authors suggest further study to determine patient or physician factors which lead to disparities in prescribing practices.
Rosenheck, 1994 | Utilization of mental health services by minority veterans of the Vietnam era | To examine racial differences in mental health utilization among Vietnam era veterans. | Cross sectional analysis | 1698 | Outpatient | All male veterans who participated in the VA National Vietnam Veteran Readjustment Study. The excluded persons who listed themselves as both Black and Hispanic. | Blacks, Whites, Mexicans, Puerto Ricans and others. | Veterans who served in the armed forces during the Vietnam War era. | Self-Report | Survey data: Outcomes measured as answers to questionnaires | Chi square analysis and multivariate logistic regression | age, religious affiliation, educaiton, income, health insurance, receipt of VA benefits, military experience, criminal justice history, violent behavior, work status and marital status, physical functioning, PTSD severity, psychiatric comorbidity, | Blacks and Mexicans were less likely to use non-VA mental health services compared to Whites. They were also less likely to use self-help groups compared to Whites. Puerto Ricans were less likely to state that they would never need help for mental illness. | Differences were present, however, the criteria for statistical significance did not take into account multiple comparisons except to state that 1–2 out of 33 differences are expected at the 0.05 level. The authors suggest that cultural differences in powerlessness or distrust may account for the observed differences in health utilizaiton.
Rosenheck, 1995 | Effect of clinician-veteran racial pairing in the treatment of posttraumatic stress disorder | To determine racial differences in patient participation, treatment and treatment outcomes in Patients with PTSD enrolled in the VA PTSD Clinical Team Program | Retrospective cohort study. | 4726 | Outpatient | All veterans seen as a part of the VA PTSD Clinical Team Program/excluded if not Black and not White | Whites and Blacks | Veterans with PTSD enrolled in the VA PTSD Clinical Team Program | Self-Report | Pariticpation was measured using 24 measures from the period clinical progress summaries of the program, content of emphasis in treatment questionnaires, prescriptions given and clinician assessment questionaires. | Analysis of variance, chi square tests, analysis of covariance and Tukey tests. | age, marital status, combat exposure, PTSD severity, psychiatric problems, substance abuse, income and service connection status at baseline. Clinicians gender, race, professional background and veteran status and clinical site. | Blacks were had participation measures lower than that of whites in several measures. There were differences in clinical improvement. When examining physician-patient pairing, Blacks cared for by White providers had worse measures in certain areas, but equal measures in others. | The authors suggest studies of experiential training activities for current clinicians and modules addressing the specific needs of minority patients with PTSD may reduce these disparities.
Rosenheck, 1997 | Homeless mentally ill veterans: race, service use, and treatment outcomes | To determine racial differences in treatment outcomes in the Homeless Chronically Mentally Ill program and if these differences are mediated by differences in residential treatment. | Prospective cohort study | 564 | Inpatient/Outpatient | All veterans at 9 participating Homeless Chronically Mentally Ill VA program sites contacted between Dec 7 1987 and Oct 15 1988/Exculed patients who did not have 4 or more clinical contacts | Blacks and Whites | Homeless veterans suffering from pscyhiatric and or substance abuse disorders. | Self-Report | Health service utilization measured with a questionnaire with items regarding recent health service uses. Residential status measured by whether veteran had been slept in a shelter, on the street or other inadequate residence in the past 90 days. Health status measured the Global Severity Index and Addiction Severity Index. Social adjustment measured by measures of social networks. | Analysis of variance and analysis of covariance. | History of hospitalization for substance abuse, current substance abuse, ASI indices and social network scores | Blacks had significantly less improvement in ASI indices. When stratified by residential treatment, Blacks admitted to the residential treatment component had similar ASI indices and Blacks not admitted had less improvement. | The data suggest that efforts to increase admittance of Blacks to residential treatment programs would reduce disparities.
Rosenheck, 1998 | Participation and outcome in a residential treatment and work therapy program for addictive disorders: the effects of race | To examine differences in program participation and clinical outcomes between black and white veterans with addictive disorders who participated in an intensive VA residentialy work therapy program | Cross Sectional analysis. | 962 | 15 VA Compensated Work Therapy/Transitional Residence Program sites | All patiens admitted for treatment at one of the 15 VA Compensated Work Therapy/Transitional Residence Program sites between October 1990 to September 1995/Excluded were non-White or non- Black patients. | Black and White | Veterans with substance abuse or dependence disorders. | Initial assessment interview | 1)Subjective perceptions measured using the Community-Oriented Program Environment Scale and Work Environment scale. 2) Program participation measured using data on hours worked in program, money earned for rent etc. 3) Clinical improvement measured using the Addiction Severity Index and Brief Symptom Inventory | Analysis of covariance, logistic regression and factorial analysis of covariance | All demographic and clinical severity scores which differed at baseline between Blacks and Whites. | Blacks had substance dependency more often and Whites had alcoholic dependency and psychiatric disorders more often at Baseline. Blacks had more positive perceptions of the program environment. There were no differences in program participation. No interaction terms found. | Interesting in that this was a designed as a second generation study. Differences in disease at baseline existed, however, no differences in treatment were found. As such the hypothesized role of racial composition of the program work-site as a cause of racial disparities was not warranted.
Rosenheck, 1998 | Access to public mental health services: determinants of population coverage | To examine determinants of mental health service use of U.S. veterans | Cross sectional analysis | 3156 (counties) | Outpatient and Inpatient (used databases) | All U.S. counties excluding Puerto Rico. Numerator included all veterans using mental health services found in the VA patient treatment file and outpatient file for fiscal year 1995. Denominator included all potential veteran mental health users defined as the number of veterans residing in the county according to 1990 census data. | Black, Hispanic and other | U.S. veterans | Administrative record | Utilization data found from patient treatment file and outpatient files, two national VA databases on inpatient and outpatient care. | Mulitlevel hierachical linear modeling and step wise regression. | (county level variables such as percent older than 65, percent black, percent hispanic, percent with income<$10,000, percent receiving va compensation, percent receiving va pension, population density, VA per veteran-capita spending on mental health resources, non- VA per capita spending on mental health resources, and distance to mental health resources from county. | The authors found that the percentage of Blacks in the county was negatively associated with mental health utilization. Half of the variance in mental health service use was accounted for by socio-demographic factors (36%) VA system facotrs (7%) and non-VA system factors (8%). | This was a descriptive study where the unit of analysis was the county and the subgroups studied had more to do with type of psychiatric disease and VA entitlements rather than race.
Rosenheck, 2002 | Black and Hispanic veterans in intensive VA treatment programs for Posttraumatic Stress Disorder | To determine racial differences in process and outcomes in intensive PTSD treatment programs and if difference stratify by treatment program type. | Retrospective cohort | 12447 | Retrospective Cohort study | All patients enrolled into an intensive PTSD treatment program at one of 49 sites between June 1, 1993 and Jan 31 2000/Excluded patients without follow-up data 4 months later. | Blacks, Whites and Hispanics | Veteran inpatients with PTSD enrolled in intensive treatment programs. | Self-Report | Intake surveys and follow surveys with items pertaining to processes such as time spent on waiting lists, length of stay and commitment to therapy and. Items for outcome measures such as violent behavior, employment income and Mississippi PTSD severity scale. | Analysis of variance, chi square tests, and hierarchichal linear modeling. | Sociodemographic variables (presumed) and site (stated) | There were mixed results indicating processes or outcomes that favored Blacks in some areas and favored Whites in other areas. Hispanics were more satisfied with treatment than Whites. The Bonferroni correction however rendered all associations not statistically significant. | Authors do not make recommendations for further research.
Ross, 1998 | Age, ethnicity, and comorbidity in a national sample of hospitalized alcohol-dependent women veterans | To determine associations between demographic factors in women veterans with alcoholic dependency and inpatient treatment for alcoholic dependence. | Cross Sectional analysis. | 854 | National VA database: looking at inpatient setting. | Female veterans admitted with a primary or secondary diagnosis of alcohol dependency to a VAMC bed section during the 1993 fiscal year/treatment for substance dependence occurred without treatment for alcohol dependence. | White, Black, Hispanic, Native American | Female veterans with alcohol dependence admitted during fiscal year 1993 | Administrative record | Used administrative database and examined discharge records. Length of stay equal or greater than 90% of the modal length of stay for a particular alcohol dependence treatment program = complete treatment. >6 but <90% of modal LOS = partial treatment. 0–5 days or admission to a unit not a part of the treatment program = alcohol detoxification. Admitted with a secondary diagnosis of alcohol dependence and admitted to a unit part a part of the treatment program = no alcohol treatment | Chi-Square tests and multivariate regression | Age, race-ethnicity, marital status and comorbidity. | Found that Native Americans were more likely to undergo treatment than any other group after adjusting for other factors. | Authors recommend further studies to identify barriers to treatment in women admiitted for alcohol dependency in VAMCs.
Stack, 2000 | Race, age, and back pain as factors in completion of residential substance abuse treatment by veterans | To determine an association between race, other demographic factors, patient history factors and completion of substance abuse treatment. | Cross Sectional analysis. | 340 | Hampton Virginia VAMC domiciliary- based residential treatment program for substance dependency | Admission to the Hampton, VA VAMC during 1996. Excluded if the patient carried a psychiatric diagnosis that only 2% or less of the other patients also carried. Also excluded were patients who were transferred out of the treatment unit before treatment completion. | White, Black and Hispanic/other | Veterans with substance abuse or dependence disorders. | Self-Report | Administrative data were used. No definition for completion treatment was stated. | Chi square tests, t-tests and multivariate regression | Age, race, presence/absence of back pain | Blacks were more likely to complete treatment than whites. Older age was an independent predictor and race-age was an interaction term with older Blacks being most likely to complete treatment. | Authors do not make recommendations for further research.
Westermey er, 2002 | Perceived barriers to VA mental health care among Upper Midwest American Indian veterans: description and associations | To determine if perceived barriers to VA health care among Native Americans exist. If they do exist what demographic characteristics are associated with vets who perceive them and what demographic and clinical factors are associated with higher numbers of perceived barriers. | Cross Sectional analysis. | 573 | Native American urban and rural communities in Minnesota, Wisconsin and South Dakota | Unclear about age, disease status, or how the communites were chosen. Media announcements went out to make Native Americans aware that researchers were coming to the communities. It appears that any Native American veteran willing to participate in the study and sign the consent form was included. | Native Americans only. | Native Americans living in urband and rural communites in the northern mid-west. | Self-Report | Developed a method of content analysis to code for types of perceived barriers to VA health care and then group them. Subjects were asked open ended questions and tape recorded. | chi square tests and analysis of variance | none | 21% of subjects studied reported atleast one perceived barrier. Of those who perceived barriers to care there were no demographic differences between those who perceived barriers to care and those who did not. Of those who perceived barriers to care only use of traditional alternative medicine was associated with higher perceptions of barriers to care. Also, there is a significant association between those who use traditional medicine and psychiatric illness. | Interesting second generation study indirectly suggesting that by addressing perceived barriers to care Native Americans would increase their use of VA health care.
Charbonneau, 2003 | Measuring the Quality of Depression Care in a Large Integrated Health System | To examine the prevalence of guideline concordant care for patients with depression and determine the patient and provider factors that are associated with guideline concordant care. | Retersopective cohort | 12678 | Outpattient treatment | All patients with specific ICD-9 codes for depression generated during FY 98 and FY 99, who also had a prescription for an antidepressant between June 1 1999 and August 31 1999/Excluded patients with comorbid psychiatric illneses as well as patients with prescriptions for trazadone, TCAs or bupropion | Black, White and perhaps others (unclear) | Veterans in the Northeastern U.S. with a diagnosis of depression. | Administrative record | Used the centralized pharmacy database to calculate the average daily dosage of medication and the adequate duration of treatment. | Chi square analysis and logistic regression | age, sex, race, marital status, service connection, medical comorbidity, type setting of outpatient care, | With regard to race the authors found that Blacks were significantly less likely than Whites to receive adequate dosage of antidepressant or adequate duration of treatment of antidepressant. | Race was not the primary predictor variable of interest in this study, but was one of many covariates in the logistic regression model.
Valenstein, 2006 | Patient and Facility-Level Factors Associated with Diffusion of a New Anti- Psychotic in the VA Health System | To determine the magnitude of adoption of Ziprasidone a new anti-psychotic among psychotic patients in the VA health system and determine which patient level factors and VA facility factors were most closely associated with this adoption | Cross Sectional analysis | 104082 | Outpatient | All patients with a ICD-9 codes for schizophrenia or schizoaffective disorder generated during Fys 2001 2002 and 2003 as well as received a prescription for an anti-psychotic during the same year. | Black, White, Hispanic, Asian, Native American and unknown | U.S. veterans with schizophrenia or schizoaffective disorders on prescription medication | Administrative record | Used national VA pharmacy data to determine if ziprasidone was filled during the year in which the ICD-9 code was generated. | Generalizing estimation equations | Age, race, sex, medical comorbidity index, concurrent diabetes, concurrent cardiovascular disease, psychotic illness severity, facility region and academic affiliation. | Blacks compared to Whites and Hispanics compared to Whites had a lower odds of receiving Ziprasidone in each of the fiscal years examined. A significant interaction between race and diabetes and race was found with White diabetics being more likely to recieve Ziprasidone than Native American or Asian diabetics. Also among those with more severe pscyhosis (those with psych admissions in the previous year) Whites were more likely to receive Ziprasidone than Blacks. | The authors suggest that racial differences in physician-patient communication and patient preference may explain the racial differences in medication use. Of note is that ziprasidone was non- formulary during fiscal year 2001 and thus socioeconomic variables may help explain racial differences during this time period. Though these variables were not adjusted in the model.
Young, 1999 | Patient, Provider, and Treatment Factors Associated with Poor-Quality Care for Schizophrenia | To determine which patient and provider factors are most predictive of poor-quality care for patients with schizophrenia or schizoaffective disorder. | Prospective cohort study | 224 | Outpatient | Had schizophrenia or schizoaffective disorder, betweent he ages of 18 and 65, had attended clinic for atleast 3 months, had not had significant hospitalization stay during the past 3 months and had been seen by a psychiatrist atleast once in the past 3 months. | Blacks and Whites and unclear | Outpatients with schizophrenia or schizoaffective disorder with ongoing care at one of two outpatient clinics. | Self-Report | Used published guidelines, patient interviews and medical records to measure poor-quality of medical management, poor- quality of symptom management and poor- quality of side-effect management | logistic regression | Age, sex,. Race, disease severity, compliance, patient insight, patient knowledge of disease, duration of illness, failure to document symptoms in the medical record, failure to document side- effects in the medical record | With regard to race there was not a strong case for disparate outcomes. Race was a significant predictor of poor side-effect management with the result occuring in Blacks more often thatn Whites. However, the model in which race was a predictor was not itself significant. | The authors note that while there results regarding poor-quality of side- effect management in Blacks are not overly robust, they are consistent with other studies and may represent problems with doctor-patient communication.

EVIDENCE TABLE 7 VA-BASED STUDIES OF RACE AND QUALITY OF PREVENTIVE AND AMBULATORY CARE

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race/ethnic groups compared | Characteristics of study pop | Source of race data | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Results, describe qualitatively | | | | Comments
Ambriz, 2004 | Use of smoking cessation interventions and aspirin for secondary prevention: are there racial disparities? | To examine whether disparities exist in guideline- recommended secondary treatment for CAD by assessing racial differences in the use of aspirin and smoking cessation interventions in a cohort of patients with established CAD. | Baseline survey and chart review. | 1045 | 5 VA hospital sites (Atlanta/Decatur, GA; Durham, NC; Houston, TX; Pittsburgh, PA and St. Louis, MO) | Diagnosis of CAD. | African American and white | 236 African American; 809 white and 98% male. | Self-report. | Data from the patient medical record was abstracted including comorbid medical conditions, contraindications to aspirin therapy, smoking history, referral to smoking cessation therapy and medication use. Demographic data were obtained from both the medical record and the survey. | Descriptive statsitics, chi-square tests to test use of aspirin and smoking cessation intervention. Continiousvaribale assesed with t- tests. | Patients without containdications included in the aspirin analysis and current smokers were included in the smoking cessation analysis. | African American ever/current smokers 148/77 white ever/current smokers 506/248 There were no difference between the race groups in the rate of current or previous tobacco use, although whites were more likely to be current heavy smokers. African Americans and whites were equally likely to receive smoking advise or to be prescribed smoking cessation medications. Also, no difference among African American and white patients in terms of comorbid conditions and being prescribed smoking cessation. Ever prescribed smoking intervention: African American 55.8% whites 56.1% (p=.97) Of the 742 who were ideal candidates for aspirin therapy, 129 were African American and 417 were white. There were no differences betweenthe race groups in the rate of aspirin therapy (AA 74.1%, w 73.4%). Subgroup analysis showed that among hypertension patients African Americans were more likely to receive aspirin therapy (AA 83%, w 76% p=.05). Among patients with hypercholesteramia and previous CVA, white patients were more likely to receive aspirin HPCH AA 55%, w 66.1%, p=.01 and CVA AA 8.8%, w 14.4% p=.04). | | | | Data reveal need for improvement overall in use of these interventions. Limitations are that it is data based on chart review so it may underestimate aspirin use and health care providers intervening about smoking.
Bean-Mayberry, | Brief report: lack of a race effect in primary care ratings among women veterans | To report on the effect of race on primary care satisfaction among women in the Department of Veterans Affairs as part of a study examining primary care quality and satisfaction among women veterans. | Anonymous mail survey to a stratified random sample | 1447 | VA Primary care clinics or women’s clinics in 5 states (Delaware, Kentucky, Pennsylvania, Tennessee, West Virginia) | Women veterans who were patients of VA primary care or women’s clinics. Inclusion required completion of the following information on their survey: race, outpatient VA site, a regular VA provider, gender of provers, use of VA provider for regular gynecological service. | White, black and other (nonwhite/nonblack) Hispanic ethnicity was included as a covariate. | Women veterans White 1234 (85%) Black 164 (11.3%) Other 49 (3.4%) | self report | Mail survey using validated component of Primary care index with a focus on the domains of patient preference for provider, interpersonal communication, accumulated knowledge, and coordination of care. In addition the satisfaction item from outpatient VA satisfaction surveys was used. | Multivariate logistic regression | patient demographics, health status, healthcare experience, cluster by site | Race was not associated with any primary care domain or satisfaction. Black women were younger unmarried, educated, of higher income, and reported female providers and gynecolgical care in VA more often. | | | | The author comments that these promising results require that the perceptions of equity must be validated with process or outcomes data that measure quality.
Bosworth, 2006 | Racial differences in blood pressure control: potential explanatory factors | The research sought to determine the social, economic, and physical factors that may explain racial differences in blood pressure controls and determine the extent to which modifiable and non- modifiable factors are related to blood pressure control. | Patients were enrolled in The Veteran Study to Improve the the Control of Hypertension. They completed a structured interview (more like a survey) and the medical record was used for BP data. | 569 | Durham VA Medical Center Primary Care Clinics | Included patients had been diagnosed in an outpatient encounter as hypertensive and had filled a prescription for hypertensive medication. Excluded patients were severely ill or compromised. They had been hospitalized for stroke, MI, or coronary artery revascularization, diagnosed with metastatic breast cancer, had a dementia diagnosis, lived in a nursing home, received home health care, or had severely impaired hearing or speech | African American and white | 98% male veterans 41% African American 59% white | self-report | Blood pressure obtained from the VA computerized medical record. Other variables obtained from patient interview: health literacy, perceived risk associated with hypertension, understanding of medications, locus of control, knowledge of hypertension, financial situation, smoker or not, exercise or not, experience with medication side effects, view of providers communication behavior, amount of emotional support, whether relatives had hypertension, use of blood pressure monitor, diabetic or not, and adherence to medication. | Descriptive statistics and then 3 sets of logistic regression analysis (race and BP control, race and mediators of BP control, mediators and BP control). | Analysis adjusted for significant mediators of blood pressure control: non adeherence, functionaly illiteracy, having a family member with hypertension, perceived seriousness of HTN, experierencing frequent urination. | First analysis revealed that African Americans were more likely to have inadequate blood pressure control compared with whites (AA 63% vs, w 50%, p<.003; OR 1.70, 95% CI 1.2–2.41). Second analysis showed that African Americans were more likely to be non adherant (OR 1.81, 95% CI 1.28–2.58), were more likely to perceive high BP as very serious vs. serious (OR 1.75, 95% CI 1.16–2.63), to report a relative with HTN (OR 3.44, 95 CI 1.77–6.71), to be illiterate (OR 2.89, 95% CI 2.04–4.10) and to report increased urination (OR 1.63, 95% CI 1.39–2.82). Poor blood pressure medication adherence (or 1.47, 95% CI 1.02–2.1, increased perceived seriousnes of HTN vs. not serious (1.91, 95% CI, 1.06–3.46), and increased urination (OR 1.98, 95% CI 1.39–2.82) were significantly related to poorer blood pressure control. In the final model odds of AA having poor blood pressure control remained significant (1.59 95% CI, 1.09–2.29). Increased urination also remained significant (OR 1.79, 95% CI 1.24–2.57). | | | | Limitations include that the study took place at one VA medical center and that the findings may not be generalizable to women. Also, there may be additional mediators of blood pressure control not included in the analysis. Adherence was self report and it could be that there were racial differences in interpretation of the question. Further work is needed to validate measures of medication adherence in different racial and ethnic populations. Programs to improve hypertension treatment and control should focus on a better understanding of differences in the prevalence of hypertension of determinants of hypertension control among minority groups in the US.
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | To evaluate rates of physicians’ recommendations for colorectal cancer-screening tests and patietns’ completion of these tests among white and African American veterans who received care at an urban VA general medicine clinic. | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | Male veterans aged older than 50 who had scheduled appointments between May 1, 2001 and December 30, 2002. Patients with a family or personal history of colon cancer or polyps were excluded as were those who were not white or African American. | African American and white | African American : 480; white 425 | Medical record | Potential subjects were identified in a pool of patients who were 50 or older who had a primary care appointment between May 1 2001 and December 30, 2002. Unscreened patients were followed form the time of their index visit until they received a colorectal cancer screening test; 1 year had elapsed; or the study completed on June 30, 2003. | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | Among the 905 unscreened patients: physician recommendation rates for colorectal cancer screening were similar | | | | VA has in place the Colorectal Cancer Quality Enhancement Research Initiative and the External Peer Review Program, which may have positively affected rates of physician recommendations to all patients. This study is limited in that it is set in one urban VA that has twice the proportion of African American veteran patients than the VA national average. Also, some screening may have occured in non-VA facilities.
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | FOBT | | African American 2.3% white 2.8%
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | Flex Sig or colonscopy | | African American 44.6% white 44.9%
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | FOBT and flex sig or colonscopy | | African American 24.1% white 20.5%
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | Any screening (all tests) | | African American 71% white 68.2%
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | Actual screening rates for African Americans were 1.3 times higher than those for white veterans
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | FOBT | | African American 16.9% white 11.5%%
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | Flex Sig or colonscopy | | African American 16.5% white 14.8%
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | FOBT and flex sig or colonscopy | | African American 2.9% white 2.6%
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | Any screening (all tests) | | African American 36.3% white 28.9% (p=.03)
Dolan, 2005 | Colorectal cancer screening among African-American and white male veterans | | Prospective tracking of the VA electronic medical record. | 905 | Primary care clinic at Chicago VA Medical Center | | African American and white | African American : 480; white 425 | Medical record | | Screening rates compared using z-tests age and number of physician visits were compared using independent sample t-test. | Adjustments were made for clustering of patients by physician (3 attending and 57 residents in the clinic) and age. | These results did not change significantly after adjustments for age. Receipt of colonoscopy was around 9% for both white and African American veterans. Also, 40% of 1599 eligible patients were uptodate in their screening and rates of screening were similar between white and African American veterans.
Fu, 2005 | Ethnic disparities in the use of nicotine replacement therapy for smoking cessation in an equal access health care system | To examine ethnic variations in the use of nicotine replacement therapy (NRT) in an equal access health care system (VA). | Cross sectional telephone survey of a population-based sample | 1606 | Eighteen VA Medical centers (March–December 2000) | This analysis included current male veteran smokers who had had 3 or more primary care visits between October 1, 1998 and September 30, 1999. Respondents had completed the screening and had returned thier consent forms. Individuals with 10 or more psychiatric visits were excluded. This analysis did not include women or male veterans who identified thie ethnicity as Asian or Pacific Islander, Native American, and other. | white but not hispanic, black or African American but not Hispanic, Hispanic or Latino | white, 1153 (72%); African American 307 (19%); Hispanic or Latino 146 (9%) | self report | Investigators used self report measures of NRT use (defined as using nicotine patch or nicotine gum) : 1) use of NRT in the part 12 months and 2) any past NRT use. Primary analysis examined use of NRT among smokers with a serious quit attempt in the past 12 months (quit attempt lasting longer than 24 hours). | Chi square and t-tests initially. Used multiple logistic regression to evaluate ethnicity and use of NRT. | Adjusted for variables known to be related to ethnicity and smoking cessation: age, education, income, marital status, level of nicotine dependence, readiness to quit, social influence, and smoking duration. Also adjusted for facility prescribing policy. Repeating analyes using generalized estimating equations had no effect on outcome, nor did applying sampling wieghts to the logistic regression. | Sample characteristics: white smokers were older and reported high level of education. African Americans reported lower incomes levels and were more likely to receive medical assistance. Hispanic smokers were younger, reported lower levels of education, and were more likely to be employed. White smokers started smoking at a younger age and were more dependent based on the measure of time to first cigarette after waking. Hispanic smokers were more likely to report experiencing social pressue to not smoke. African Americans (55%) were more likely to have attempted quitting compared to Hispanic (43%) and white (43%) smokers. Unadjusted analysis showed that African American smokers (34%) and Hispanic smokers (26%) however were signficantly less likely than white smokers (50%) to have ever used NRT as a cessation aid. After data adjustment the results were similar. African American odds ratio (OR) of ever using NRT .57, 95% CI, .43–.75, p<.001; Hispanic OR of ever using NRT .35, 95% CI, .23–.52, p<.001. 724 of the sample had made a serious quit attempt in the last year. African American smokers were significantly less likely than white smokers to use NRT during a serious past year quit attempt as well (unadjusted African American OR .47, 95% CI 31–72 p< 001) Hispanic smokers were also less likely than white to use NRT | | | | Size and diversity of this population based sample are strengths. The limitations are that it relied on self-reported use of NRT. Also, there could have been response bias because the overall participation rate was low (of 26,966 identified eligible VA primary care users, 33% were unable to be reached and 29% refused to participate.) If the burden of tobacco related diseases is to be reduced for ethnic minority smokers, culturally sensitive interventions need to be developed to increase the use of pharmacotherapy. To inform such an intervention further research is needed to 1) examine the role of the patients’ health beliefs and preferences regarding NRT and pharmacotherapies and 2) assess the contribution of practitioner behavior and the effect of system-level polices and practices on the use of NRT.
Rehman, 2005 | Ethnic differences in blood pressure control among men at Veterans Affairs clinics and other health care sites | To determine if the VA healthcare system, which provides equitable access to care and medication, does better at reducing disparities in blood pressure control between African American and white hypertensive men than healthcare provided outside VA. | retrospective | African American men: 4379 VA patients 2754 non-VA, white men: 7987 VA patients and 4980 non-VA patients. | VA data was from the VA electronic medical record. Non-VA data was obtined from electronic medical records or data cards completed at the time of clinic visit. | Hypertensive male (BP of 140 over 90 mmhg recorded on 3 or more visits, or if patient was prescribed antihypertensive medication) | African American and white | African American men: 4379 VA patients 2754 non-VA, white men: 7987 VA patients and 4980 non-VA patients | Patient records. | Comparison of the most recent blood pressure readings recorded in patient medical records. | Investigators used descriptive statistics, chi-square for initial comparisions and multivarialbe logistic regression was run separately for whites and African Americans to compare between sites of care and account for confounding factors. | Age, BMI, comorbid disproders of lipid and glucose metabolism, cardiovascualr disease, heart failure and nephropathy, and RUCA code rural vs. urban location. | Among VA patients Whites were older than African Americans 66.1 years vs 62.3 years), had lower mean blood pressure (137/75 for white 140/79.9 for African Americans) and were more likely to have BP controlled at the last visit. African American and white veterans received a similar number of prescriptions at VA sites (1.76 for African Americans vs. 1.73 for whites). African Americans, however, has more clinic visits in the previous year (4.53 vs. 4.12, p<.001). | | | | Analysis limted to mediical practices in South Carolina and may not be generalizable outside the southeast. Limitation: ethnicity data were missing in approximately one-fourth of patients at VA and non-VA sites.
Straits-Troster, 2006 | Racial/Ethnic differences in influenza vaccination in the veterans affairs healthcare system. | To characterize racial and ethnic differences in receipt of influenza vaccination in a sample of VA users afed 50 and older and to identify factors that may be batteris to or facilators of vaccination. | secondary data analysis | 117,614 | VA outpatient Survey of Healthcare Experiences of Patients (SHEP) November 2003–March 2004. | completed survey, including race information, non-duplication | Hispanic, American Indian/Alaska Native, non-Hispanic black, Asian/Pacific Islander and on-Hispanic white | VA outpatients older than 50 years seen at VA facilties during the 2003–2004 flu season. | self-report | Investigators used answers from 4 SHEP questions. | Data was weighted for probability of selection and nonresponse. Multivariate logistic regression was used to claculate and comparte adjusted caccination prevalence among racila/ethnic groups. Chi-square analysis used to identify faciliators and barriers to vaccination among racial/ethnic groups. | Adjusted for age, gender, marital status, employment status, income, education, having a primary care provider, confidence/trust in providers, and overall health status. | Unadjusted analysis showed that non-Hispanic blacks (70.9%), American Indian or Alaska Native (74.1%) and Hispanics (79.0%) were significantly less likely to report having been vaccinated compared to non-Hispanic whites (82.1%). Age accounted for most of the racial/ethnic differences, although non-Hispanic blacks were still significantly less likely to report influenza vaccination compared to non-Hispanic whites. Unadjusted prevalence of influenza vaccination for each ethnic group: white, non-Hispanic 82.1% (CI, 81.7–82.6); Black, non-Hispanic 70.9 (CI, 69.2–72.6); Hispanic 79.0% (CI, 76.8–81.0); American Indian/Alaska Native 74.1% (71.1–76.9); Asian/Pacific Islander 84.4 (80.0–87.9). Adjusted prevalance of influenza vaccination for each ethnic group: white, non-Hispanic 81.2% (CI, 80.7–81.7); Black, non-Hispanic 75.0 (CI, 73.3–76.7); Hispanic 79.9% (CI, 77.7–82.0); American Indian/Alaska Native 78.5 (75.8–81.2); asian/Pacific Islander 84.8 (80.9–88.7). Compared to non-Hispanic whites, non-Hispanic blacks and Hispanics were more likely to report that a reminder by a healthcare provider influenced the decision to get a flu shot (39.8% vs. 58.7% black, non-Hispanic and 54.5% Hispanic (p<.01). Unvaccinated blacks and Hispanics were more likely to report that the did know know that they needed a flu shot than non-Hispatic whites (9 5% blacks and 16 8% | | | | While racial/ethnic differences in vaccination rate were noted the authors assert that “the observed racial/ethnic differences cannot necessarily be interpreted as caused by ethnic/disparity or bias” because they did not assess whether the patients who asserted that they did not want the flu shot were adequately informed.
Washington, 2002 | Racial variations in Department of Veterans Affairs ambulatory care use and unmet health care needs. | To describe racial and ethnic variation in VA ambulatory care use and to examine the association of these variations with the presence of unmet health care needs. | secondary data analysis | 7549 | 1992 National Survey of Veterans | Male veterans for whom race/ethnicity was recorded who had at least one ambulatory care visist in 1992. Women and those ineligible for VA care due to ineligible discharge or because of service limited to the reserves were also excluded. | white, black, Hispanic, American Indian or Eskimo, and Pacific Islander | white (85.4%), black (9.6%), Hispanic (3.7%), American Indian or Eskimo (.8%), and Pacific Islander (.5%) | self-report | Investigators used data collected from the 1992 National Survey of Veterans (NSV). The behavioral model of health services utilization guided this investigation. The researchers used the following NSV variables: age, education, employement, annual income, source of health insurance, marital status, service connected disability status, disatnce to VA facility, self-reported health status, number of medical conditions, limitations in activities of daily living and instrumental activities of daily living, ambulatory care use (VA- only, dual VA and non-VA use, and non-VA only). Two variables were derived rather than taken directly from the NSV: unmet medical need was derived from answers to three questions about needed medical treatment, outpatient care or hospital services and a financial barrier to care was based on a question about foregoing needed treatment due to inability to pay. | Investigators used comparative statistics, computed odds ratios and used logistic regression to analyze the data. | For the analysis of VA ambulatory care utilization the authors report adjusting for predisposing sociodemographic, enabling and health-related need characteristics. Having a service-connencted disability, any ADL limitiation, and increasing number of medical conditions were associated with increased VA use. Higher education, higher income, retirement status and having insurance were associated with lower liklihood of VA use. Age, martial status, not working as a result of disability and having any instrumental ADL limitation were not associated with likelihood of VA use. In examining the data for disparities in unmet medical needs, the researchers adjusted for a the type of ambulatory care received, VA- only, non-VA and NA, or Non-VA only use. Also, having any health related IADL limitation and a greater number of medicla conditions were associated with a greater inability to get needed care. Being retired, having highincome, having pivate medical insurace and having a service-connected disability rating of 50% or greater were all associated with lower inability to get needed medical care. | The results indicate racial and ethnic variation in VA ambulatory healthcare use and in unmet health care needs among veterans. After data adjustments black, Hispanic, and American Indian/Eskimo veterans were more likely to use VA ambulatory care than white veterans while Asian/Pacific Island veterans were slightly less likely to use VA ambulatory care. (With white veterans as the reference the odds ratios were: black OR 2.5, CI 2.0,3.2, p=.0001; Hispanic 1.5, CI 1.1,2.1, p=.02, American Indian/Alaska Native OR 1.5, CI.5,2.3, p=.86 and Asian/Pacific Islander OR .8, CI .3, 2.1, p=.68). Overall, 6.4% of veterans reported they were unable to get needed medical care at some point in the 12 months preceding the study but they were unable to get it due to lack on insurance or financial barrier. American Indian/Eskimo, Hispanic and black veterans were 4.4, 2.5 and 1.9 times respectively more likely than whites to report having been unable to get neded care (p=.0001). However, after adjusting for VA health care use or not and other sociodemographic and other variables, the data show that American Indian/Eskimo (OR 2.9, CI 1.3, 6.2, p=.006) and Hispanic (OR 1.8, CI 1.1, 2.7, p=.011) veterans were more likely than white veterans to report an inability to get needed medical care. VA-only users were less likely than non-VA only users to report an inability to get needed medical care however those who use both VA and non VA healthcare had the greatest inability to obtain needed medical care (OR 1.5, CI 1.1, 2.0, p=.01). | | | | VA operates as a safety net health care provider and in that capacity helps to reduce unmet health are needs for some veterans. Outreach efforts to improve access to VA ambulatory care should target groups with insurance barriers, poor health status and other unmet health care needs. Periodic assessment of the prevelance of unmet health care needs among veterans and of facilitators for improving VA ambulatory care access and for reducing unmet needs, represent one strategy for planning and measuring VA progress toward its goal of serving the increasingly diverse veteran population. Limitations: Respondents were all male. The NSV cannot reach those without a telephone or homeless or institutionalized veterans. The small sample size for American Indianc/Eskimo and Asian Pacific Islander veteran populations may have led to type II error. becasue this is a secondary sata analysis, there is a lack of detailed ethnic and veteran identity information. Also the number of visits to the VA, which is the variable used, does not necessarily translate to better or mnore appropriate care.
[Washington, 2005 #2040] | Racial/ethnic variations in veterans' ambulatory care use. | Assess racial/ethnic variations in patterns of ambulatory care use among Department of Veterans Affairs health-care eligible veterans to determine if racial/ethnic differences in health care use persist in equal-access systems. | Telephone survey. | 3227 | VISN 22 (southern CA and southern NV) users and non-users of VA care. | Male veterans were included in the sample if the were honorably discharged and self-identified as one of the four target groups (Asian/Pacific Islander, Black, Hispanic, and white). VA users were identified through VA patietn lists VA nonusers were identified through random digit dialing of the VISN 22 population. | Asian/Pacific Islander, black, Hispanic, and white | 27% white; 28% black; 28% Hispanic, 8% Asian/Pacific Islander | self-report | Investigators hired the Gallup organization to conduct a telephone survey of VA-eligible veterans. They collected demographic information, including race, age, education, employment status, marital status, period of military service, income and health insurance. VA users included VA only users and dual VA/non-VA users. Non-VA users were those who exclusively received ambulatory care outside the VA. Nonusers of healthcare were those who reported no healthcare visits in the previous 12 months. Variables relating to ambulatory care utilization: usual source of health care, number and location of ambulatory care visits, whether patient has a usual provider and if that provider was a resident or attending physician or a nurse or some other typs of provider. VA sures were asked their main reason for using the VA and non-users were asked about their reasons for not using VA health care. Health related measures: overall health, disability status, number of medical conditions from a list of common diagnoses. Functional limitations were also measured. | Bivariate analysis followed by logistic regression analyses. | For determining racial/ethnic differences in use of ambulatory care adjustments were made for sociodemographic and health related measures thought to be related to health care use. | Overall, 38.3% of respondents reported no healthcare visits in the 12 months, 12.3% reported VA use, and 49.4% reported non-VA only ambulatory care use. Unadjusted odds ratios for use of ambulatory care were lower for Hispanic veterans and black veterans. After adjustments these differences remained. Minority veterans were less likely to use the VA compared to white veterans. | | | | These findings suggest that doctor-patient communication is an area that the VA needs to continue to target for intervention. Study limitations: respondents grouped in 4 broad race categories; limited to south CA and souther NV; did not assess distance to care; female veterans were excluded.
[Washington, 2005 #2040] | Racial/ethnic variations in veterans' ambulatory care use. | | Telephone survey. | 3227 | VISN 22 (southern CA and southern NV) users and non-users of VA care. | | Asian/Pacific Islander, black, Hispanic, and white | 27% white; 28% black; 28% Hispanic, 8% Asian/Pacific Islander | self-report | | Bivariate analysis followed by logistic regression analyses. | For determining racial/ethnic differences in use of ambulatory care adjustments were made for sociodemographic and health related measures thought to be related to health care use. | Asian/pacific Islander | | OR .4, 95% CI .3,.7
[Washington, 2005 #2040] | Racial/ethnic variations in veterans' ambulatory care use. | | Telephone survey. | 3227 | VISN 22 (southern CA and southern NV) users and non-users of VA care. | | Asian/Pacific Islander, black, Hispanic, and white | 27% white; 28% black; 28% Hispanic, 8% Asian/Pacific Islander | self-report | | Bivariate analysis followed by logistic regression analyses. | For determining racial/ethnic differences in use of ambulatory care adjustments were made for sociodemographic and health related measures thought to be related to health care use. | black | | OR .5, 95% CI .4,.6 (p<.0001)
[Washington, 2005 #2040] | Racial/ethnic variations in veterans' ambulatory care use. | | Telephone survey. | 3227 | VISN 22 (southern CA and southern NV) users and non-users of VA care. | | Asian/Pacific Islander, black, Hispanic, and white | 27% white; 28% black; 28% Hispanic, 8% Asian/Pacific Islander | self-report | | Bivariate analysis followed by logistic regression analyses. | For determining racial/ethnic differences in use of ambulatory care adjustments were made for sociodemographic and health related measures thought to be related to health care use. | Hispanic | | OR .4, 95% CI .4,.3,(p<.0001)
[Washington, 2005 #2040] | Racial/ethnic variations in veterans' ambulatory care use. | | Telephone survey. | 3227 | VISN 22 (southern CA and southern NV) users and non-users of VA care. | | Asian/Pacific Islander, black, Hispanic, and white | 27% white; 28% black; 28% Hispanic, 8% Asian/Pacific Islander | self-report | | Bivariate analysis followed by logistic regression analyses. | For determining racial/ethnic differences in use of ambulatory care adjustments were made for sociodemographic and health related measures thought to be related to health care use. | Barriers to VA health care use by race and ethnicity included poor interpersonal quality of VA care reported by 30.10% overall (OR for black and Hispanic veterans 1.1 for both and 1.6 for Asian Pacific Islanders, dissatisfation with VA reported by 9.5% overall (OR for black veterans 1.7, Hispanic veterans 2.1*, and 5.8* for Asian/Pacific Islanders), and lack of knowledge about eleigibility reported by 14.6% overall (OR for black veterans .7, Hispanic veterans 1.8*, and 1.5 for Asian/Pacific Islanders).
Williams, 2002 | Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center | To evaluate compliance with National Cholesterol Education Program (NCEP) goals and Adult Treatment Panel II ATP II clincial guidelines in white and African American veterans at high risk for cardiovascular disease after implementation of a Lipid Management Program. | Retrospective chart review | 649 | VA New Jersey Healthcare System | All high-risk male patients with coronary artery disease (CAD) and/or diabetes mellitus (DM) taking simvastatin monotherapy for three months during 1999 were included. Patients who had CHD, or 2 or more major risk factors and/or diabetes were considered to be high risk. Females, those taking another statin, and those with poorly documented charts were excluded. | African American and white | 127 African American, 522 white. | Patient record | Investigators reviewed all the charts of patients taking simvastatin monotherapy for three months at the VANJHCS. The collected the following information: demographics (including race), the number of clinic visits and frequency of lab stests for lipid profiles. They also recorded pre and post simvastatin fasting TC, LDL-C, HDL-C. The presence of CHD, diabetes, hypertension, and smoking were recorded as well. | Investigators used descriptive statistics, a Fisher paired t-test, and multivariate logistical regression. (I cannot locate the results from the logistic regression in the manuscript.) | NR | African Americans had significantly higher baseline total, LDL-C, and HDL measures than white patients. Additionally, African Americans experienced a significantly greater decline in LDL-C after simvastin therapy. Nonetheless, African American veterans were less likely to acheive the target LDL-C measure of 100 dg/mll (40.94% African Americans acheived it while 56.9% of white veterans acheived it (p=.001). There were no significant differences in HDL-C elevation or TG levels between the groups. Below find the averages: | | | | This study was not designed to determine the reason for racial variation in compliance to the guidelines. New VA guidelines to achieve LDL-C below 100 mg/dl should improve the results.
Williams, 2002 | Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center | | Retrospective chart review | 649 | VA New Jersey Healthcare System | | African American and white | 127 African American, 522 white. | Patient record | | Investigators used descriptive statistics, a Fisher paired t-test, and multivariate logistical regression. (I cannot locate the results from the logistic regression in the manuscript.) | NR | African American total cholesterol | 217.5 mg/dl | White total cholesterol | 193.5 mg/dl | This study was not designed to determine the reason for racial variation in compliance to the guidelines. New VA guidelines to achieve LDL-C below 100 mg/dl should improve the results.
Williams, 2002 | Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center | | Retrospective chart review | 649 | VA New Jersey Healthcare System | | African American and white | 127 African American, 522 white. | Patient record | | Investigators used descriptive statistics, a Fisher paired t-test, and multivariate logistical regression. (I cannot locate the results from the logistic regression in the manuscript.) | NR | African American LDL-C | 137.9 | White LDL-C | 113.3 | This study was not designed to determine the reason for racial variation in compliance to the guidelines. New VA guidelines to achieve LDL-C below 100 mg/dl should improve the results.
Williams, 2002 | Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center | | Retrospective chart review | 649 | VA New Jersey Healthcare System | | African American and white | 127 African American, 522 white. | Patient record | | Investigators used descriptive statistics, a Fisher paired t-test, and multivariate logistical regression. (I cannot locate the results from the logistic regression in the manuscript.) | NR | African American HDL | 45.9 | White HDL | 42.9 | This study was not designed to determine the reason for racial variation in compliance to the guidelines. New VA guidelines to achieve LDL-C below 100 mg/dl should improve the results.
Williams, 2002 | Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center | | Retrospective chart review | 649 | VA New Jersey Healthcare System | | African American and white | 127 African American, 522 white. | Patient record | | Investigators used descriptive statistics, a Fisher paired t-test, and multivariate logistical regression. (I cannot locate the results from the logistic regression in the manuscript.) | NR | African American LDL-C declined | 24.6% | White LDL-C decline | 15.1% | This study was not designed to determine the reason for racial variation in compliance to the guidelines. New VA guidelines to achieve LDL-C below 100 mg/dl should improve the results.
Williams, 2002 | Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center | | Retrospective chart review | 649 | VA New Jersey Healthcare System | | African American and white | 127 African American, 522 white. | Patient record | | Investigators used descriptive statistics, a Fisher paired t-test, and multivariate logistical regression. (I cannot locate the results from the logistic regression in the manuscript.) | NR | African American total cholesterol declined | 23.4% | White total cholesterol decline | 16.1% | This study was not designed to determine the reason for racial variation in compliance to the guidelines. New VA guidelines to achieve LDL-C below 100 mg/dl should improve the results.
Williams, 2002 | Racial differences in compliance with NCEP-II recommendations for secondary prevention at a Veterans Affairs medical center | | Retrospective chart review | 649 | VA New Jersey Healthcare System | | African American and white | 127 African American, 522 white. | Patient record | | Investigators used descriptive statistics, a Fisher paired t-test, and multivariate logistical regression. (I cannot locate the results from the logistic regression in the manuscript.) | NR | Note that African Americans and white were not signifcantly different in the rates of hypertension and statin dose. Compared to whites, African Americans had less heart disease, greater rates of diabetes, more of them were smokers, and more of them were likely to be obese. African Americans also had a higher number average of clinic visits and lipid profiles. I cannot lcoate the results of the | | | | This study was not designed to determine the reason for racial variation in compliance to the guidelines. New VA guidelines to achieve LDL-C below 100 mg/dl should improve the results.
Woodard, 2004 | Is lipid-lowering therapy underused by African Americans at high risk of coronary heart disease within the VA health care system? | To examine whether racial differences exist in cholesterol monitoring, use of lipid lowering agents, and acheivement of guideline recommended LDL levels for secondary prevention of coronary heart disease. | Baseline surveys and medical records (secondary to another study). | 1045 | 5 VA hospital sites (Atlanta/Decatur, GA; Durham, NC; Houston, TX; Pittsburgh, PA and St. Louis, MO) | Initially patients identified through cardiac imaging studies. Those that showed evidence of reversible cardiac ischemia were eligible. Exclusions occurred because patients: could not be contacted, had impaired mental status, enrolled in another cardiac study, were not African American or white, underwent cardiac procedure in the preceding 6 months, were not veterans, died before enrollment, or refused to participate. | African American and white | 236 African American; 809 white | self report | Investigators used computerized medical records to determine documented lipid levels (total cholesterol and LDL within 3 months or enrollment or during the study), appropriateness for treatment with lipid-lowering therapy, medication use, contraindications to lipid-lowering medication and coexisting medical conditions. Patients provided demographic information in the survey. | Descriptive and bivariate analysis (chi square and t-tests). | | While only only two-thirds of patients received screening, African Americans and whites were equally likely to to receive cholesterol monitoring (64.8% vs. 67.6% p=.42). Of those receiving screening African Americans and whites had similar mean cholesterol values (194 mg/dl vs. 188.7 mg/dl p=.27). Among all patients African Americans were less likely to receive lipid-lowering agents; however, when analysis was restricted to the 544 patients who met the definition of ideal candidate fro treatment with lipid-lowering agents, African Americans and whites were equally likely to receive treatment (96.9 vs. 98.9, p=.96). African American and white patients were equally likely to acheive target LDL levels (32.8 vs. 41.4% (p=.21). Furthermore, mean LDL levels were similar among patients of both races that did not acheive target LDL levels (African American 141.9 mg/dl vs. 134.7 mg/dl p=.18). | | | | Cholesterol readings for patients who may have been screened outside the three month window of the study were not included. Data in this analysis were obtained for a study assessing racial differences in patient attitudes regarding the use of invasive cardiac procedures. Sample was 98% male therefore findings not generalizable to women. Sample was limited to those with documented coronary heart disease and therefore cannot be applied to those who have not yet been diagnosed.
Woodard, 2005 | Racial differences in attitudes regarding cardiovascular disease prevention and treatment: a qualitative study | To explore coronary heart disease (CHD) health care expereinces and beliefs of African American and white veterans to elicit potential causes of racial disparities in CHD outcomes. | Focus groups stratifed by race transcribed and analyzed for themes. | 24 | VAMC Houston | Patients recruited from a list of 354 patients who had previously participated in a study assessing health beliefs and use of invasive cardiac procedures. A convenience sample of 66 patients were contacted by telephone and 33 agreed to participate. Reasons for nonparticipation included illness, transportation difficulty, scheduling conflicts, and disinterest. | African American and white | 14 white and 10 African American: Group 1: 8 white males, 56–75 years old; Group 2: 6 white males, 57–68 years old; Group 3: 4 African American males 48–83 years old; Group 4: 6 African American males 52–80 years old. | NR | Thematic analysis of focus group transcripts by four qualified investigators. | Thematic analysis. | NA | Four themes emerged in the discussions: Risk-factor knowledge, physician-patient communication, access to care, and treatment beliefs. African Americans diverged from white counterparts in that they reported experiencing racism and they displayed less specfic knowledge of cardiovascular risk factors and the impact of these factors on heart disease. Overall the findings suggest lower health literacy among African American patients. Both whites and African Americans agreed that physicians need to listen to and acknowledge patient concerns as well as effectively convey information about medical conditions. Most participants indicated that their willingness to comply with physician recommendations was related to the length of time they knew the physician. Racial differences in physician-patient communication were revealed in the level of patient assertiveness, with whites being more likely to be assertive than African Americans. Both groups reported similar difficulties in accessing care and both groups attributed their porblems in access to their low socioeconomic status. Regarding treatment beliefs: white participants believed that perhaps they would receive better care from health care providers if they could pay and African Americans worried that the generic medications used by the VA were not as effective as brand name | | | | Findings suggest that strategies to improve risk factor knowledge and to enable African American patients to become active partners in their medical care may lead to improved CHD morbidity and mortality in this population. The efficacy of such an intervention would need to be tested in further work.

EVIDENCE TABLE 8 VA-BASED STUDIES OF RACE AND QUALITY OF REHABILITATIVE AND PALLIATIVE CARE

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race groups compared | Source of race data | Characteristics of study pop | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Results, describe qualitatively | Comments
Hwang, 2003 | Knowledge and attitudes toward end- of-life care in veterans with symptomatic metastatic cancer | 1) to describe the knowledge and attitudes about end-of-life (EOL) care of veterans with symptomatic metastatic cancer, 2) to explore the relationship between race and EOL preferences, and 3) to explore the association between patient-perceived health status and survival | Cross- sectional survey | 254 | VA New Jersey Health Care System (VANJHCS) | From 1999–2002, included symptomatic advanced cancer patients with distressing symptoms, defined as presenting with at least “somewhat” distress for a minimum of one physical symptom or at least “occasional” frequency for a minimum of one psychological symptom measured by the Memorial Symptom Assessment Scale-Short Form (MSAS-SF), seen in the outpatient Hematology/Oncology clinic and the inpatient service, participated in the Unmet Needs Project, and completed the Vermont Voices on Care of the Dying Questionnaire. Excluded 38 patients with regional-advanced stage disease, and 4 patients without VVCDQ data. | Black v. white | NR | Patients with advanced cancers. 100% male Median age 69 (range 29– 96) 53.2% Caucasian 42.9% Afr Am Other race (3.9%) | Vermont Voices on Care of the Dying Questionnaire (VVCDQ) | Chi square test | None | Blacks had significantly higher responses than whites in the following: Uncertainty about their current health situation: 40.3% v 23.7% Lack of knowledge about hospice: 77.1% v 46.7% Absence of terminal care documents: 72.5% v 49.7% Desire for bad news to be discussed with family or friends first 13.8% v 3.7% Uncertainty about preferred location of death: 57.8% v 31.8% Blacks had significantly lower responses than whites in the following: Knowledge of severity of illness: 38.5% v 53.3% Desire for frankness when breaking bad news: 79.8% v 90.4% Preference to die at home: 32.1% v 51.1% Belief that the current health care system is not doing a good job in addressing the needs of patients with pain: 3.7% v 12.6% or in taking care of dying persons 0.9% v 8.9% Significantly more black than white patients died in the hospital: 78.4% v 52.9%, p<0.0001. | Disparites in advanced planning, EOL decision making, and location of death
Braun, 2005 | Decreasing use of percutaneous endoscopic gastrostomy (PEG) tube feeding for veterans with dementia-racial differences remain | To determine temporal and racial trends over the past decade in the incidence of PEG tube placement in veterans with dementia. | Retrospectiv e cohort study | 6464 | All VA hospitals | Veterans aged 60+ who were discharged from a hospital stay during 1990–2001 with a diagnosis of dementia. A subset of patients who subsequently received a PEG tube was identified. | Black vs. non-Hisp. white | Admin. records (PTF) | 98% male, mean age 75 | 3 VA databases: patient treatment file (PTF) which contains all discharges from all VA hospitals, outpatient clinic (OPC) file, and the Beneficiary Identification Record Locator Subsystem (BIRLS). | logistic regression | Race, age, comorbidities, geographic region, fiscal year, and statistically significant interaction terms. | RR for PEG tube placement (95%CI) by race: White 1.00 (-ref-) Afr Am 1.77 (1.68–1.87) Hisp 0.89 (0.77–1.04) Other 0.97 (0.71–1.33) Unk 0.45 (0.30–0.68) Blacks were 77% more likely than whites to have a PEG tube placed. 18.4% of patients with dementia were blacks, 28% of all PEG tube recipients were blacks. Temporal change in use sig. differed by race. Among whites: 1.1% in 1990, increased to 1.7% in 1994, down to 1.1% in 2001. Among blacks: 1.8% in 1990, 3.0% in 1996, down to 2.1% in 2001. The year of highest PEG tube use occurred 2 years later for blacks than white dementia patients. | More aggressive/less palliative end-of-life tx among blacks
Horner, 2003 | Effects of race and poverty on the process and outcome of inpatient rehabilitation services among stroke patients | To examine racial differences in time to initiation of stroke rehab services and in the trajectory of physical function recovery | Secondary analysis of a prospective cohort study | 738 | 9 VA sites; VA Acute Stroke (VAST) study | 738 black or white patients with acute stroke who were hospitalized within VHA between 1995–1997 for acute ischemic or intracerebral hemorrhagic stroke and referred to inpatient rehabilitation. | Black v. white | Self-report. Medical record was used if self-report was missing. | 31.2% black 98.2% male | Medical record review and telephone interviews after discharge. Pts followed up from admission through 1 yr after stroke onset. | Least-squares regression to analyze race by length of time to initial contact by rehab svc personnel | Age, sex, marital status, living situation at discharge (alone, with others, or nursing home or institution), income level, stroke type and severity, cognitive function, and whether care was directed primarily by a neurologist, and #days from stroke onset to admission. | There was no racial difference in total number of in-hospital contacts with rehab personnel, in the proportion of stroke patients who were referred to inpatient rehab, or the intensity of rehab. Patients did not differ by race in receipt of inpatient rehab services 76% of blacks v 70% of whites) or in the proportion of pts referred within 3 days of admission (43.5% of blacks and 42% of whites). Average time to initiation of rehab was approximately one-half day longer for blacks than whites (3.8 v 4.4 days, p<0.05), resulting from a greater proportion of blacks than whites (8% v 4%) being referred to rehab >=10 days after admission. Low-income black pts had a greaer likelihood than higher-income blacks of beginning inpatient rehab beyond 3 days (47% v 27.3% of low v higher- income black pts, p<0.04). This association did not occur among white pts (low 41.8% v high- income 40.5%).
Hwang, 2004 | Study of hormone refractory prostate cancer: hospital care and palliative care resource use at a VA medical center | To report data on hospital care, palliative care resource use, and survival for patients with hormone refractory prostate cancer (HRPC) | Retrospective chart review study | 89 | VANJHCS | Included records of consecutive patients who died of prostate cancer between 1994 and 1999 and were treated by the Section of Hematology/Oncology at VANJHCS from the time of documentation of HRPC to death. Excluded patients who had only biochemical relapse (worsening PSA antigen). | Black v. white | Medical record | Died of prostate cancer. Mean age at time of stage D3: 73 (range 52–96). 43% black 57% white | Patient medical record | Chi-square test | None | Blacks and whites did not differ significantly on % who died in hospital (54% v 64%), or who were referred to hospice care (49% of blacks v 34% of whites), or who used opioids (89% of blacks v 88% of whites). There were no racial differences in duration of hospice care or type of medications used in the last 6 months of life, except more blacks used appetite stimulants (43% v 18%, p=0.01) and fewer blacks used anxiolytics (11% v 41%, p=0.002). A greater proportion of blacks than whites received physical therapy (65% v 42%), p=0.03), blacks had a greater number of admissions than whites (3 times v 2 times, p=0.01).
Casarett, 2002 | Does a palliative care clinic have a role in improving end-of-life care? Results of a pilot program | To assess the efficacy of a palliative care clinic that provided some of the interdisciplinary services and expertise of an inpatient consult service to outpatients, in traditional clinic sessions; to determine whether an ambulatory population can provide sufficient patients for a palliative care clinic; to define the survival of patients referred to palliative care clinics in order to determine whether follow-up is possible; to understand a clinic’s role in relation to other services. | Prospective study of an intervention pilot program | 100 | Pilot palliative care outpatient clinic at Philadelphia VAMC | One hundred patients seen over a 16 month period. 54% were referred to the palliative care clinic by the geriatrics services, 24% by oncology, and 22% by primary care. | Black v. white | Self-report via interview | Cancer 85% Dementia 8% Mean age 68.2 (range 41–88) 99% Male 64% black 33% white 1% Asian 2% other race | The clinic team (physician, chaplain, social worker, pharmacist) collected basic demographic info on all patients, including marital status and income. Follow-up was conducted by phone with patient or family, or communication with primary care provider. | Predictors of hospice enrollment were tested in bivariate Cox proportional hazards models. Significant variables were included in a multivariate model. | Outcome: earlier enrollment in hospice. Variables: need for help at home, a determination of hospice eligibility, ethnicity, Global Distress Index (GDI) score, do not resuscitate (DNR) status, | 65 of 100 patients were eligible for hospice at the first visit., and 42 (65%) enrolled in hospice during the follow-up period. For patients who enrolled in hospice, median time between initial visit and enrollment was 4 days, but ranged from 0–389. Race was significantly associated with early hospice enrollment, in an analysis that adjusted for Global Distress Index and other variables. The HR for early hospice enrollment was 2.52 comparing white patients to non-whites (95%CI 1.24–5.09). | This is a pilot intervention to improve quality of care, and reported disparities by race. Black patients delayed hospice enrollment longer than did other patients, consistent with other studies that have found that blacks are less willing to give up life-sustaining treatment through DNR orders and advance directives (see refs 29 and 30). Authors note that they have begun to identify reasons for delays in referral - has this been published?

EVIDENCE TABLE 9 VA-BASED STUDIES OF RACE AND QUALITY OF CARE IN OTHER CLINICAL AREAS

See MS Excel spreadsheet

Author, Year | Title | Aims | Study design | N subjects | Setting | Incl/Excl criteria | Race groups compared | Source of race data | Characteristics of study pop | Type of outcome: describe | Outcome data source/methods of outcome assessment | Analytic method | Variables adjusted for in analysis | Results, describe qualitatively | Comments
Arozullah, 1999 | Racial variation in the use of laparoscopic cholecystectomy in the Department of Veterans Affairs medical system | To evaluate whether the rate of adoption of laparoscopic cholecystectomy and improvements in the duration of postoperative hospitalization differed between African- American and Caucasian patients. | Retrospective cohort study; prospective cohort study | 16181 in PTF, 5029 in prospective dataset | National VA database and NSQIP | PTF file: hospitalizations during the year before introduction of laparoscopic cholecystectomy (1991) and the first 4 years of the procedure’s use (1992–1995). Selected veterans who had a primary or secondary diagnosis of gallbladder disease and also underwent an open cholecystectomy or a laparoscopic cholecystectomy. Prospective nurse-compiled dataset: patients enrolled in the National Veterans Affairs Surgical Quality Improvement Program, (NSQIP) Phase I (1991–1993) conducted at 44 VAMCs that were affiliated with university medical centers and offered both cardiac and noncardiac surgery. Phase II: 1994–1995 was conducted at 132 VAMCs that perform major surgery. Included all noncardiac operations performed under general, spinal, or epidural anesthesia. Selected patients who underwent open cholecystectomy or lapraroscopci cholecystectomy, and a postoperative diagnostic code for gallbladder or biliary disease. Excluded race other than black or white. | Black v. white | PTF data | Underwent open or laparoscopic cholecystectomy PTF data: 1932 blacks, 94.8% male 14249 whites, 94.8% male Nurse-compiled dataset: 639 blacks, 96% male 4336 whites, 95.6% male | Use of laparoscopic vs open cholecystectomy during the index admission. Also analyzed mortality and length of stay. | PTF dataset; Nurses prospective dataset: Preoperative data were collected from charts, patient interviews, or from a surgical risk profile completed by surgical resident. Patients were followed 30 days after index operation. | Multiple logistic regression for predicting the use of laparoscopic vs open cholecystectomy. | PTF: adjusted for race, age, marital status, geographic region, comorbid illness, and year of surgery. Nurses data: adjusted for demographic values, preoperative lab values, and clinical characteristics | PTF data: Among patients undergoing cholecystectomy at VAMCs 1992–1995, 35.4% of black patients and 42.6% of white patients underwent laparoscopic cholecystectomy (p<0.001). After adjustment for potential confounders, blacks were 0.74 (95%CI 0.66–0.83) times as likely as whites to undergo the laparoscopic procedure during the 4 study years. Nurse-compiled prospective clinical data set: Laparoscopic cholecystectomy was performed in 22.1% of black patients and 28.6% of white patients (p<0.001). After adjustment for confounders, blacks were 0.68 (95%CI 0.55–0.84) times as likely as white patients to undergo laparoscopic vs open cholecystectomy. Open cholecystctomy was significantly associated with greater operative mortality compared with laparoscopic cholecystectomy: OR 3.03, 95%CI 2.11–4.34) and unadjusted mortality was higher among blacks than whites (1.44, 1.05–1.96), but in analyses that adjusted for type of cholecystectomy and other confounders, mortality did not significantly differ by race. | among patients who underwent cholecystectomy, blacks had an approximately 25% to 32% lower likelihood than whites of undergoing minimally invasive cholecystectomy procedures. The differences in rates of adoption of laparoscopic surgery did not appear to be from more comorbid illnesses among black patients. It is not clear whether patients differ by race in their preference for new surgical procedures, or whether VA physicians may have been less likely to recommend laparoscopic cholecystectomies to black patients.
Basson, 2004 | Informed consent for screening sigmoidoscopy in a Veterans Administration population | To test the hypotheses that current consent methods may not convey the data that we imagine that they do, and that many patients may not want the data that we believe that we ought to provide. We also argue that excessive and unthinking emphasis on informed consent documentation may ignore real and important issues. To assess whether patients were giving informed as well as legal consent, by examining in detail whether patients understood the indications for a screening flexible sigmoidoscopy, its associated risks, benefits, and alternatives, and the name of their treating physician. | Cross-sectional survey | 59 | Single VAMC | Male patients consecutively scheduled for screening sigmoidoscopy were interviewed before and after the procedure in a tertiary care academic health center. | Nonwhite v. white | Self-report | Males scheduled for sigmoidoscopy 10% black 8% Hispanic 78% white Mean age 66.4, range 50–82 | Interviewers asked patients questions about their understanding of the procedure, receipt of preparatory materials. The postprocedure interview took place within 15 minutes after sigmoidoscopy, and asked if patients knew the name of their sigmoidoscopist and asked details about how the exam had been explained to them, including benefits and risks and alternative screening methods. Patients were asked how much of the consent form they had read before signing, and if they had felt comfortable proceeding with the exam at taht point. Also assessed patient knowledge of polyps and colorectal cancer and the significnace of the results of sigmoidoscopy. | At the time of the sigmoidoscopy, each patient was asked a series of standardized questions before and after the examination by an interviewer unaffiliated with the sigmoidoscopy and consent process. The primary care physicians and sigmoidoscopists were blinded to the study. | Bivariate analyses, chi2 | None | A similar lack of informed consent was observed across all ethnic groups studied, ioncluding being informed of risks and alternatives to the proposed procedures. E.g. 60% read none of the form; 14% read all of the form; 14% had never heard the word “polyp” before; 39% could describe no indication other than doctor recommendation Despite this lack of informed consent, most of the patients failed to ask further questions of their physicians and claimed that they had sufficient information to proceed with the procedure. 27% of nonwhites associated polyp with malignancy 78% of whites associated polyp with malignancy (p=0.001). | Authors note: despite insufficient knowledge, patients comfortably proceeded with the sigmoidoscopy, simply because their primary care physician had recommended it. Authors note: the striking ethnic difference we found in understanding the relationship between polyps and cancer mirrors other ethnic-based differences in patient beliefs about health and disease and emphasizes the need to engage patients in answering questions, as this may emphasize important issues to them as well as remind physicians of the variations in the patient’s baseline knowledge and sbusequent comprehension.
Curtis, 1995 | Use of the medical futility rationale in do-not-attempt-resuscitation orders | To estimate the frequency of use of the medical futility rationale, determine whether residents use the rationale to avoid talking with patients about end-of-life issues, and assess residents’ understanding of medical futility. Medical futility has been considered by some to be an ethically acceptable rationale for physicians to withthold CPR without necessarily offering the procedure to patients. Ethicists have expressed concern that medical futility cannot be clearly defined, that it involves hidden value judgments, and that it may undermine the principle of patient autonomy - particularly regarding qualitative futility, i.e. the intervention is futile because it will not produce an acceptable quality of life. | Cross-sectional survey | 44 medicine residents; 145 inpatients | 1 VAMC and 1 municipal hospital | Included all 2nd and 3rd year internal medicine residents leading inpatient medicine or cardiology teams, telephoned weekly and briefly interviewed about each patient (n=145) who received a DNAR order in the preceding week. Inpatients on medical wards and in medical and coronary intensive care units at 1 VAMC and 1 municipal hospital, both incorporated the medical futility rationale into their DNAR policies at least 3 years before the study. | Nonwhite v. white | Reported by medical residents | Of 44 residents: 25 were women (57%), 40 were non-Hispanic whites (91%). Of 4 nonwhites, 2 were Asian, 1 was black, 1 was Native American. Of 145 patients: 27 nonwhites: 14 blacks 10 Asian/Pacific Islander 2 Hispanic 1 Native American 11% female 2/3 of patients were hospitalized at the VAMC, 1/3 at the municipal hospital | 1) whether the residents invoked quantitative futility and 2) whether residents invoked qualitative futility. | Scripted phone interviews conducted 0–23 days after a DNAR order was written. Questions about the patient included demographics, underlying chronic illnesses, and acute medical conditions; organ failiure; functional status, immobile, in intractable pain or discomfort, or unable to communicate. Probability of patient surviving to hospital discharge after CPR. Residents were asked whether 1) patient or surrogate choice and 2) medical futility applied to the patient. Residents were asked whether quantitative and/or qualitative futility applied to the patient | Logistic regression using forward-selection, stepwise; generalized estimating equation approach used to account for lack of statistical independence btw interviews by the same resident. | Age, sex, patient race, medical conditions with a prevalence of >5%, presence of any organ failure; functional status variables; resident’s prediction of patient’s survival | Residents reported that in all cases they discussed the DNAR order with either the inpatient attending physician or the individual patient’s primary care physician before writing the order. When medical futility was invoked without patient or surrogate choice, DNAR orders were discussed with all patients who could communicate - indicates that medical futility is not being used to avoid discussing with patients the issues surrounding DNAR orders. Residents reported that medical futility applied in 91 (63%) of the 145 DNAR orders and was the only rationale for the DNAR order in 17 (12%). In these 17 cases, quantiative futility applied to 7, qualitative futility to 6, and both to 4. In a multiple regression model, factors associated with the application of quantitative futility (i.e. a very low or no likelihood of surviving to hospital discharge after (CPR) were organ failure, nonwhite race, and probability of surviving to hospital discharge. Adjusted OR (95%CI0 of quantitative futility associated with nonwhite race: 2.7 (1.1–6.3) Controlling for hospital site had minimal effects on the estimates (results not shown). Factors associated with the application of qualitative futility were age and immobitility as independent predictors. Patients >=75 were the least likely to have resdients judge that qualitative futility applied to CPR; hospital site had minimal | Race was a strong predictor for use of the quantitative-futility rationale even after controlling for severity of disease and for the residents’ prediction of CPR survival. Authors suggest as one explanation that perhaps whites were more likely to request DNAR orders when futility was not perceived, creating the association between race and quantitative futility. However, since resident’s prediction of the probability of surviving CPR was controlled for, this finding suggests that residents may have been influenced by race per se in determining quantitataive futility. Race was not a predictor for the application of qualitative futility. Hospital records were used to estimate number of DNAR orders written: DNAR orders were written on 9.7% of admissions and an estimated 150 DNAR orders were written during the study period, compared with 152 DNAR orders recalled by residents - sampling and recall fairly consistent.
Damron-Rodriguez, 2004 | Accessibility and acceptability of the Department of Veteran Affairs health care: diverse veterans’ perspectives | To describe 5 overarching themes of meaning veterans give to their interaction with VA health care; to outline implications for accessibility and acceptability of VA services from the veterans’ discussion of their perceptions. | 16 focus groups | 178 | NR | Veterans were recruited by various means, including community-based strategies to recruit minority veterans. 16 focus groups were stratified by war cohort and racial background. WWIII + Korean Conflict vs Vietnam +Persian Gulf War; race groups were black, Asian, Euro-, and Hispanic. | Black, Asian, Euro, Hispanic | NR | 174 community-recruited veterans, stratified by war cohort; includes Black, Asian, Euro, Hispanic but Ns not specified. | Assessment of veteran status and VA health services; Access - knowledge of benefits, value benefits as deserved, concern about welfare stigma from use of VA health services; Acceptability - aware of physician attentiveness, expect employee respect as a veteran | Focus groups were videotaped and audiotaped. | Transcription coding and qualitative analysis QSR N*UDIST | None | Overall, focus group participants indicated that it was not necessary for doctors to be of the same racial/ethnic group as their patients to effectively treat them. They did insist on the importance of physicians’ true concern for their patients’ health and welfare. When asked if veterans preferred their physician to be of the same ethnicity, only 8 of the 174 participants expressed that preference. | Only 1 finding relevant to review; other findings do not compare by race.
Davis, 1994 | An assessment of practitioner cross- racial treatment experiences | To determine differences in the cross-racial practice experiences of white and minority social services practitioners. | Cross-sectional survey | 53 counselors | 1 VAMC outreach center | 53 counselors employed by the VA who provided counseling services to Vietnam veterans in outreach centers in the southeastern US. | Nonwhite v. white | Self-report | VA social work counselors 43 men 10 women 33 whites 20 nonwhites: 17 black, 3 native American | by questionnaire, counselors were asked: how successful do you think you are in working with minority clients? With white clients? Level of perceived success was on a scale of 1 (not successful) through 7 (very successful) Counselors were asked to indicate which factor they believed contributed most to their white and minority client’s problems: the clients themsleves, other people, or situations in clients’ environment. | Questionnaire filled out by counselors while attending a training conference | ANOVA | None | White (m=5.60) and minority counselors (m=5.79) perceived themselves to work about equally well with white clients. White counselors (m=4.66) perceived themselves to be less successful with minority clients compared with minority counselors (m=6.20). The differences were significant (p<0.0001). Both white and minority counselors did not differ in their identification of the source of client problems. However, both white and minority counselors perceived a difference in the source of the problems experienced by white versus minority clients: the source of white clients’ problems was perceived by 62 of counselors to exist within the clients themselves. In contrast, the source of minority clients’ problems was perceived by 62% of counselors to be a function of situations in client’s environment. Minority counselors reported a greater frequency of racism during cross-racial counseling experiences (m=4.10 for minority counselors, m=5.01 for white counselors, p<0.01). White counselors reported that their non-white clients perceived them to have insufficient understanding of what it means to be a member of the client’s racial group (m=4.95 for minority counselors, m=3.87 for white counselors, p<0.02). | Authors suggest: for minority counselors, preparation for cross- racial practice should include time spent develping strategies to prevent and address perceived racist behaviors of their clients. For some white clients, working with a minority practitioner may be inconsistent with their perceptions of the status hierarchy of white- minority interactions. Both white and minority practitioners may need to be more cognizant of their class biases in their perceptions and subsequent treatment of client difficulties. This consideration is especially relevant for low-income white clients who may be ascribe dgreater responsibility for their misfortunes than is warranted by their social realities and life opportunities.
Flaherty, 1981 | Racial differences in perception of ward atmosphere | To confirm previously observed perceptual differences of the ward environment among white and black inpatients, and to examine their breadth and magnitude. | cross-sectional survey | 34 | Psychiatric ward of 1 VAMC | Males aged 20–62, 17 black and 17 white inpatients in the psychiatric ward of a VA hospital. | Black v. white | Not described | Male psychiatric inpatients 17 blacks 17 whites | Questionnaire of Ward Atmosphere Scale | 2 consecutive administrations of the Ward Atmosphere Scale was given to 2 groups of patients on a 20-bed psychiatric ward. | Bivariate analyses, chi2; stepwise discriminant analysis on the 10 subscales to determine within-group homogeneity and the predictive capacity of the WAS in regard to race. | Not reported | Whites had higher mean scores than blacks on the following WAS subscales: Involvement 6.88 v 5.06, p=0.017 Spontaneity 4.82 v 3.11, p=0.005 Autonomy 5.76 v 4.47, p=0.008 Personal problem orientation 5.65 v 4.17, p=0.019 Anger and aggression 5.82 v 4.36, p=0.049 There were no significant differences on the subscales for support, practical orientation, order and organization, program clarity, and staff control, but mean scores were higher among whites compared with blacks. In the stepwise discriminant analysis, 79.4% of all patients in the sample could be correctly classified by race on the basis of their WAS subscale scores. This result also indicates that in regard to perception of ward atmosphere each group was relatively homogeneous. | the analysis did not adjust for age, chronicity, or SES, though previous surveys of different patients on the unit had shown general racial agreement on these factors. Blacks rated the ward lower on all 10 subscales, although only 50% of the subscales showed a significant difference between race groups. Explanatory mechanisms were not studied. Authors suggest that a negative perception of inpatient treatment is likely to result in low compliance during outpatient treatment, which could have deleterious effects on the long-term functioning of patients who have major psychiatric disorders and need medication maintenance, though this correlation was not studied.
Gordon, 2002 | Process of care in Hispanic, black, and white VA beneficiaries | To examine whether process of hospital care differs among Hispanic, blakc, and white VA beneficiaries | case-control study | 2852 | a case-control study in 12 southern VAMCS | Hispanic, black, and white males from a case-control study discharged from 1 of 12 southern VA hospitals with one of 3 diagnoses: diabetes, congestive heart fialure, or chronic obstructive pulmonary disease, between 1987–1989. Patients were selected for a retrospective case control study of the relationship between quality of care and readmission. PTF file of all inpatient hospitalizations was used to identify the first admission within the study period for patients with 1 of the 3 diagnoses. All patients readmitted within 30 days of the index stay were enrolled in the study. Controls were matched with cases based on hospital, diagnosis, and 1 of 4 6-month periods of hospital discharge. Excluded patients who died during the index hospitalization or during postdischarge period, because not at risk for readmission. Excluded patients transferred from another acute care hospital or who left against medical advice. | Hispanic, black, white | PTF | 875 patients with CHF (22.7% black, 4.3% Hispanic) 1299 patients with COPD (12.4% black and 2.2% Hispanic) 678 patients with DM (25.5% black and 5.3% Hispanic) | Computed adherence score: the percentage of applicable criteria performed during the hospital stay, using diagnosis-specific explicit criteria for process of hospital care. Criteria were categorized with respect to timelien of hospitalization: 1( admission work-up, 2) evaluation and treatment during hospital stay, and 3) readiness for discharge. | Chart review | Bivariate analyses; chi2 or ANOVA | Stratified analyses of admission adherence scores by hospital teaching status, severity of illness, number of previous hospital stays, and age. | There were no statistically significant differences in the number of applicable admission, treatment, or discharge criteria by race for congestive heart failure, COPD, or diabetes. Mean admission adherence scores were significantly higher among blacks with CHF and COPD but were similar for DM. Mean treatment and discharge scores were similar among Hispanic, black, and white patients. In stratified analysis, patients admitted to a teaching hospital had higher admission and treatment scores compared with non-teaching hospitals. Process of inpatient care did not differ by race after adjusting for admission to a teaching hospital and other covariates. | Process of inpatient care was similar overall in Hispanic, black, and white patients.
Graveley, 1991 | Multiple drug regimens: medication compliance among veterans 65 years and older | To develop a profile to identify veterans over 64 who might be at risk for medication noncompliance | Prospective cohort study | 319 | 1 VAMC in South Texas. | Male veterans aged 65+, English-speaking, living within a 30-mile radius of the hospital, having from 1–7 oral daily prescribed medications, and agreed to a clinic interview and 2 home visits. The sample was drawn over a 7-month period from patients being followed for chronic conditions at the General Medicine Clinic of a large VHA in South Texas. | Nonwhite v. white | Self-report (clinic interview) | Males with chronic conditions prescribed 1–7 oral medications 89 Hispanics 17 blacks 9 Asians 134 whites | Definition of compliance: between 80–110% of the dose taken for any of the prescribed medications. | Scales to determine relationship to compliance were Paired-Associate Test, the Mini Mental State, the Multidimentsional Health Locus of Control, and the Standard Depression Scale. Compliance was determined by pill count made at 2 home visits. The 1st home visit was 1 wk after clinic interivew; the 2nd home visit was 2 weeks later. | Stepwise logistic regression to predict noncompliance. | Age, SDS index, MMS score, number of pills, and marital status | 78% of enrolled subjects completed both home visits. Bivarite analyses: ethnicity was significantly associated with compliance: whites: 33% compliant non-whites: 18% compliant (p=0.009) Multivariate analyses: ethnicity was a significant predictor of noncompliance: OR for noncompliance comparing non-whites to whites = 1.44 (p=0.03) The other significant predictor was Number of pills per day (OR 1.05, p=0.03). | Ethnicity was an independent predictor of noncompliance. No explanatory mechanisms were studied or proposed.
Groeneveld, 2006 | Racial differences in attitudes toward innovative medical technology | To measure how innovativeness varies among patients and how it may influence patients’ attitudes toward new medical technologies. | cross-sectional survey | 171 | Philadelphia VAMC | Included veterans in primary clinics at the Philadelphia VAMC, 2004–2005. Veterans in clinic waiting areas were asked to volunteer for the study via periodic verbal announcements and posters. Excluded 19 respondents who indicated more than 1 racial group or that race was neither white nor black. | Black v. white | Self-report | urban primary care patients, 60–65% with cardiovascular disease 108 blacks 63 whites | Self-administered survey (5-point Likert-scale) with 6-items on attitudes toward new concepts in general, and 6 items on attitudes toward new medical drugs, devices, and procedures. Questions were derived from previously validated instruments. A final component was a vignette describing either a hypothetical implantable device or new prescription drug, each to reduce risk of heart disease. Questions asked about their attitudes toward the new technology. | Respondents completed a paper version of the instrument while seated in the clinic waiting area. Study staff attempted to rectify any ambiguous or illegilbe written responses in consultation with the respondents. | OLS regression models | sex, age, annual income < $20k, not having completed high school, having cardiovascular disease, having >2 comorbid conditions, having <2 prior medical procedures, and the risk-attitude score | In multivariate analysis, black race was not a significant predictor of general innovativeness (p=0.59). In multivariate analysis black race was significantly associated with lower medical technology innovativeness scores (p=0.01), with the expected difference in innovativeness score being 0.24 points lower for blacks compared with whites. For the vignettes, in multivariate analysis, there was no significant racial difference in attitutdes toward a hypothetical new medical device (p=0.33). However, for the vignette about a hypothetical new prescription drug, blacks (p=0.01) were less favorably oriented than whites. Multivariate regression results (95%CI) indicating the expected change in innovativeness score for blacks versus white: General innovativeness: −0.06 (−0.26 to 0.15) p=ns Medical technology innovativeness −0.24 (−0.42 to −.0.06)* Device vignette 0.11 (−0.11 to 0.34) Drug vignette −0.36 (−0.64 to −0.08) Blacks (16%) were more likely than whites (6%) to agree with the statement: I would avoid a new prescription drug, medical device, or procedure if I had not heard about it from several people other than just my doctor (p=0.09). However, blacks (12%) did not significantly differ from whites (8%) in agreement with the statement: I rarely trust new ideas until I can see whether the vast majority of | Study found differing attitudes toward medical innovation in response to particular health care technologies. Whites had higher medical technology innovativeness and were more likely to accept the neew prescription drug, but did not differ from blacks in acceptance of the new implantable device. Lower medical technology innovativeness among blacks was significantly associated with less favorable reactions to bot the prescription drug and the medical device vignettes. Whites with lower medical technology innovativeness were also less inclined to accept the new implantable device, but there was no association between med tech innovativeness and attitudes toward the new prescription drug among whites.
Julapalli, 2005 | Evaluation for liver transplantation: adherence to AASLD referral guidelines in a large Veterans Affairs center | To estimate the magnitude and determinants of consideration of liver transplantation at the referral level in patients at a single, large VAMC. | retrospective cross- sectional study | 199 | Michael E. DeBakey VAMC | Electronic records generated a list of patients with liver disease seen in outpatient or inpatient departments in 2002–2003. Included patients who had one or more of the following indications for referral, based on AASLD guidelines: variceal bleeding, ascites, spontaneous bacterial peritonitis, porrto-systemic encephalopathy, hepatocellular carcinoma, hepatorenal syndrome, fulminant hepatic failure, or a Child-Turcotte-Pugh score of 7+ exclusive of another indication. Excluded patients without confirmed liver disease or potential indications for transplant referral. | Black, Hispanic, v white | Medical record | Patients with liver disease 98% male 44 (22%) blacks 23 (12%) Hispanics 132 (66%) whites 50% HCV 4% HBV | Primary outcome: mention of liver transplantation in the medical record. Outcomes collected from medical record: 1) any mention of liver transplantation within 1 year of encounter; 2) documented intention of referral for possible liver transplant; 3) documented consultation initated by a referral. | Standardized forms used to data collect at the earliest encounter at which the indicate for referral was documented. Data included demographics, etiology and severity of liver disease, potential contraindications to liver transplantation, and adherence to guidelines for referral for liver transplant. For encounters that did not result in mention or referral of transplant, they ascertained reasons for the lack of mention/referral - either documented or inferred. | Multivariate logistic regression | age, race, HCV, HBV, alcoholic liver disease, spontaneous bacterial peritonitis, encephalopathy, child-Turcotte-Pugh B or C class, active alcohol use, and congestive heart failure. | Among all patients, only 21% (41 of 199) who had an identifiable potential indication for liver transplant had any mention of liver transplantation in the medical record. Black race emerged as a significant, independent negative predictor. There was an 85% decrease in the odds of mentioning liver transplantation as compared with whites (p=0.045). Adjusted OR (95%CI) of mention of liver transplantation in encounters with patients satisfying AASLD referral guildeines for possible liver transplantation, by race: White (reference) Black 0.15 (0.02–0.96), p=0.045 Hispanic 0.12 (0.01–1.40) p=0.09 There were no significant differences between blacks and whites in age, or insurance other than VA (14% of blacks vs 20% of whites, p=0.32). However, blacks had statistically significant differences from whites in the prevalence of alcohol liver disease (61% of blacks v 81% of whites, p=0.01) and HCV (64% of blacks v 42% of whites, p=0.02). | Alcoholic liver disease and black race were independent predictors of an lower likelihood of mentioning liver transplantation. Authors note the limitation that study depends on the accuracy of documentation of discussions pertaining to liver transplantation, and that undocumented attitudes of patients and providers toward liver transplantation might have influenced mention of liver transplantation in the medical record.
Kressin, 2003 | Racial variations in dental procedures: the case of root canal therapy versus tooth extraction | To determine if there is racial variation in use of root canal therapy vs tooth extraction across different levels of dental insurance coverage and adjusting for other factors known to influence treatment decisions. | retrospective cohort study | 54423 | national VA database | 54,423 patients who had received any tooth extraction or root canal therapy in fiscal year 1998, selected by computerized procedure code. Excluded extractions of teeth with full bony impactions (they represent prophylactic extractions of third molars). | Hispanic, black, Asian, white | PTF; “race is assigned by the registration clerk based on visual inspection. Self-reported race data from “the 1999 Large Survey of Veterans” was also used, decreasing unknown race from 26% to 17% | Users of outpatient dental care in 1998 Native Am Indians and Pacific islanders combined as “other” race. | Dental disease severity - based on procedure codes. Patient’s first visit for root canal or tooth extraction during the designated time period was unit of analysis (80% of visits), and deleted visits in which both procedures were performed (n=127) | 3 VA data files: 1) Dental Activity System, 2) VA OPC, and 3) PTF | Multiple logistic regression | controlled for medical and psychiatric comorbidities, sociodemographic characteristics, prior use of preventive services, prior tooth extraction and root canal therapy, and clustering by geographic region. Prior use of preventive dental care was a proxy for patient’s value on tooth preservation, an indication for patient preferences. | Eligibility for dental care varied by race. Fewer blacks (24.8%) and Hispanics (38.7%), and more Asians (67.9%) and whites (45.3%) were eligible for comprehensive dental care.(p=0.0001) Frequency of root canal therapy varied by race and eligibility for VA dental care. Asians (31%) and patients with unknown race (28.9%) had the highest rates of root canal therapy, and blacks had the lowest (20.1%). After adjustment for covariates and clustering within geographic regions, blacks and those with unknown race remained less likely overall to receive root canal therapy than whites, whereas Asians were more likely to receive this therapy than whites. Adjusted odds (95%CI) of receiving root canal over tooth extraction over all types of dental care coverage, by race: White: reference Black 0.597 (p<0.05) Hispanic 0.881 (ns) Asian 1.633 (p<0.05) Other 1.130 (ns) Unknown 0.863 (p<0.05) | Blacks were less likely and Asians more likely to receive root canal therapy instead of tooth extraction, even after controlling for clinical and sociodemographic factors. There were racial vairations in dental insurance coverage in the VA, but dental insurance coverage did not eliminate variations in care. The differences were observed overall and among those with continuing and comprehensive coverage, but these difference did not persist within the other insurance subgroups.
Schneiderman, 2004 | Variations in health communication needs among combat veterans | To assess the helpfulness of different media for providing health risk communication messages from a population-based survey of health concerns and preferred sources of health risk communication among combat veterans. | cross-sectional postal survey | 1288 | Postal survey | 5000 veterans were sent survey mailing in approximately equal numbers from the Vietnam War (1964–1973), the Persian Gulf War (1991), and the Bosnia-Kosovo peacekeeping activity (1995–2002). | non-white v. white | Not described | 17% of sample, 10% of respondents were black 805 of sample, 77% of respondents were white | Participants were asked to rate the helpfulness of different media for obtaining health info on a 10-pt scale, and to answer items regarding access to and use of the Internet. | 206-item postal survey | Mean scores for helpfulness ratings were computed. Differences in internet access by race were tested with Pearson Chi2 statistic. | None | Response rate varied with combat era/age. Own doctor received the highest helpfulness rating: 7.3 among whites, 6.8 among non-whites (p=ns) Non-whites rated a variety of media more favorably than did whites, suggesting greater receptivity to a wider array of information sources. All conflict eras combined, mean helpfulness rating among whites vs non-whites: VSO newsletter 6.0 v 6.4 (p=0.04) Web site 5.9 v 6.3 (p=0.06) Television 5.6 v 6.1 (p=0.002) VA doctor 5.4 v 5.9 (p=0.008) Internet access and use was greater among whites compared with nonwhites. The difference was largest among Vietnam vets (nearly 20%, p<0.001) and narrowed over time (12% for Persian Gulf War vets, p<0.001) and 2% for Bosnia-Kosov veterans, p=ns). | These findings reinforce the role of the primary health care provider as the most helpful resource for health risk communication. These preliminary findings indicated high Internet use among veterans, suggesting that the Internet offers an important channel for delivering health risk information to combat veterans. Internet access among Vietnam veternas (77%, 50–87 years old) was higher than that among the general US population (62% of 50–58- year-olds, 46% of 59–68-year-olds).
Wei, 2003 | Ethnic disparity in the treatment of women with established low bone mass | To assess the extent of bone-health treatment and to test for racial differences in that treatment among black and white women with documented low bone mass. | Cross-sectional survey | 75 | Wash. DC VAMC | All women who underwent central dual-energy X-ray absiorptiometry (DXA) testing from 1998–2001, stratified into 3 groups based on central bone density using WHO definitions: 1) normal, T score >−1; osteopenia, T score <=−1, and >−2.5; osteoporosis T score <=−2.5. Self-administered questionnaires were mailed to those with low bone mass (T score <=−1). | black v. white | self-report | 75 women with low bone mass, 41 (55%) whites 26 (35%) blacks | The use of antiresorptive drug treatments in women with low bone mass | Self-administered questionnaires mailed to women with low bone mass | Multivariate logistic regression | Adjusted for severity of low bone mass (osteoporosis v osteopenia), and personal history of fractures (hip, wrist, or spine). | Overall response rate was 68%. Nonrespondents were similar in age, weight, height, BMI, prevalence of osteoporosis v osteopenia, and racial representation. Osteoporosis was significantly higher in whites than in blacks (49% v 285, p=0.035), and there was a nonsignificantly higher prevalence of prior fracture in whites (29% v 19%, p=ns). Black and white women did not differ significantly in rates of smoking, drinking, or regular exercise, but they did differ significantly in use of calcium supplements and antiresorptive drugs. 90% of white women v. 69% of black women were using calcium supplements (p=0.048); 71% of white women and 35% of black women were using antiresorptive drugs.(p=0.004) The difference in use of antiresorptive drugs remained significant after adjusting for severity of low bone mass (osteoporosis v osteopenia) and prior fracture (v no prior fracture): Adjusted OR (95%CI) of use of antiresorptive drugs, comparing whites v. blacks 3.71 (1.24–11.1) | Among women with DXA-documneted low bone mass, white women were significantly more likely to be taking calcium or antiresorptive medications than black women. The higher prevalence of osteoporosis and fractures among white women did not adequately explain this finding. Clinical practice guidelines recommend calcium supplements for all postmenopausal women with low bone mass, regardless of osteopenia or osteoporosis. White women were 3.7 times more likely than black women to b eusing antiresorptive medication, even after adjusting for the higher prevalence of osteoporosis and fractures among whites. Reasons for this disparity were not studied.
Young, 2000 | Patient satisfaction with hospital care: effects of demographic and institutional characteristics | To examine the extent to which a patient’s satisfaction scores are related to both demographic characteristics and the institutional characteristics of the health care organization where care was received. | Secondary analysis of patient satisfaction surveys | 34359 | primary source of data: 1997 VHA patient satisfaction survey from 135 hospitals | For both inpatient and outpatient surveys, VHA randomly selects a sample of patients from each hospital. For inpatient survey, VHA randomly selects from each hospital a stratified sample of 175 medical, surgical, and psychiatric patients. The sample is based on computerized hospital discharge abstracts, and includes patients who were discharged home within the 3 months before sample selection. The outpatient survey randomly selects using computerized outpatient records 175 patients who had 1+ primary care visit during the 2 months preceding the survey and who also had 1+ visit to a specialist during the 6 months preceding the primary care visit (to evaluate coordinate of care among providers). | Nonwhite v. white | Self-report | Across all 3 settings: 2.6–5.4% female 19.1–27.1% nonwhite | Survey data was used to examine satisfaction in 3 settings: inpatient medicine, inpatient surgery, and hospita.l-based outpatient care. Inpatient survey, 9 subscales: coordination of care, timeliness and accessibility of care, courtesy of staff, emotional support, respect for patient preferences, family involvement, physical comfort, transitions, and information and education. Outpatient survey was similar, but does not include subscales for transition or physical comfort. Both surveys ask to rate general health status. A composite score for each patient was calculated by taking the average of subscale scores. | Mail-out, mail-back surveys. | Ordinary least-squares regression, with patient satisfaction rating as dependent variable. | Demographic and institutional characteristics | Response rate was 61% for inpatient and 71% for outpatient surveys. Nonwhite patients reported lower satisfaction than did white patients, in all 3 settings. Standardized regression coefficients from ordinary least squares regression, associated with nonwhite race: Inpatient medicine −0.031 (p<0.01) Inpatient surgery −0.022 (p<0.05) Outpatient −0.040 (p<001) The inpatient model of demographic and institutional characteristics accounted for ~10% of the sample variation in patient satisfaction scores. Approximately 9% of the sample variation in satisfaction scores was attributable to patient characteristics alone. Thus, the inclusion of the institutional characteristics contributed virtually no additional explanatory power to the model. For inpatient surgery, patient characteristics accounted for virtually all of the explanatory power of the model (15% of the variation in patient satisfaction scores. For outpatient care, the model combining demographic and instiutional characteristics explained only 8% of the sample variation in satisfaction scores, which was also almost entirely attributalbe to the patient-level characteristics. | Explanatory mechanisms were not studied. Authors note that most of the variation in patient satisfaction scores for hospital care is not attributable to either the demographic characteristics of patients or the institutional characteristics of the hospitals. Thus, hospital managers and clinicians would appear to be in a position to affect patient satisfaction through improvements in service processes.

EVIDENCE TABLE 10 ONGOING AND UNPUBLISHED VA-BASED STUDIES ON RACE AND HEALTHCARE QUALITY AND UTILIZATION

See MS Excel spreadsheet

Author | Title | Content | Objectives | Study design and setting | Characteristics of study population | Results on racial disparities | Status
Arozullah, A.M. | The impact of health literacy on racial differences in cancer stage at presentation | Cancer | To determine if racial differences in the rate of advanced stage presentation for prostate, colorectal, and lung cancer can be explained by differences in health literacy, social support, use of screening tests, or both. | Cross-sectional survey at 2 VAMCs. | Black and white veterans with prostate, colorectal, or lung cancer (n=900) | Of the first 108 patients, 53 were white and 43 were black. Further findings by race not yet reported. | Ongoing; Abstract on HSR&D website
Barnett, M.J. | Lack of Racial Variation in the Use of ACE-I or ARB Therapy in Primary Care Patients with Diabetes and Hypertension | Diabetes; preventive care/hypertension | To determine if the use of angiotensin converting enzyme inhibitor (ACE-I) or angiotensin receptor blocker (ARB) therapy in patients with diabetes (DM) and hypertension (HTN) varies by race. | Retrospective cohort study. Data from OPC and Pharmacy outpatient prescription files were used to identify VA primary care patients with diabetes and hypertension during a 2-year time period (2002–2003) for whom race was captured. | 445,570 VA primary care patients with diabetes and hypertension, 74% white, 17% black, 9% other race | Rates of ACE-I or ARB use were racially similar. Rates for 6 months of therapy were identical across race. | 2006 HSR&D Annual Meeting Abstracts
Bean-Mayberry, B. | Do Gender and Race Affect Quality of Care in the VA Healthcare System? | Diabetes | To assess the degree to which gender and race mediate the performance of recommended processes of care and key intermediate outcomes for patients with diabetes. | Secondary analysis of a national dataset of outpatient veterans in the VA External Peer Review Program (2001–2003), linked with the national patient care database. | 56,632 veterans with diabetes, 15% black, 20% women. | Compared to whites, blacks had lower performances on all measures: receipt of pneumonia or influenza vaccine, fasting lipids, and uncontrolled BP. | 2007 HSR&D Annual Meeting Abstracts
Bean-Mayberry, B. | Effect of gender and race on receipt of pneumococcal and influenza immunizations in VA | Preventive care - use of pneumococcal and influenza vaccination | To assess the performance of key immunization measures by gender and race in a national sample of veterans | Cross-sectional study based on linking VA External Peer Review Program data with national patient care database. | male and female veterans (N=91,570) | Blacks had significantly lower rates of pneumococcal and influenza immunization compared with whites, in analyses that adjusted for age, marital status, VA eligibiltiy status, clinical conditions, VISN region, and culstering for repeated sampling across fiscal years. | Abstract published in proceedings of Society of General Internal medicine
Boggs, C.D. | Racial Differences in Validity of Psychometric Test Data in Veterans Being Evaluated for PTSD | Mental health | To explore racial differences in validity rates on the Personality Assessment Inventory (PAI) and the Minnesota Multiphasic Personality Inventory- 2 (MMPI-2). | Analysis of the validity of psychometric test data from veterans being evaluated for PTSD at a VA PTSD clinic. | 194 black and 121 white veterans evaluated for PTSD | Black veterans generated more invalid profiles due to elevations on scales suggestive of over-reporting on the Negative Impression Management and Infrequency-Psychopathology - scales designed to distinguish over-reporting of psychological symptoms from elevated profiles due to psychological distress. Blacks are less likely to be service connected for PTSD, and the possibility of racial bias in validity rates of psychometric tests widely used in the VA might contribute to the disproportionate denial of PTSD disability claims in blacks. | 2006 HSR&D Annual Meeting Abstracts
Bokhour, B. | Culture and communication in hypertension management | Preventive care - hypertension management; patient-physician communication | To better understand the ways in which cultural factors affect patient-provider communication and behaviors patients engage in to control their hypertension, particularly adherence to medication regimens. | Qualitative study using audiotaped clinical interactions and semi-structured interviews with patients and providers | Patients with hypertension and their providers, NOS | Not yet available | In start-up phase
Cannon, K.T. | Racial Differences in Treatment of COPD Exacerbation within the VA Healthcare System | Other - COPD | To describe racial differences in use of noninvasive ventilation and mechanical ventilation for treatment of COPD exacerbation within the VHA. | Retrospective cohort study using PTF data on all black and white patients admitted to VHA facilities during FY 2003–2005 with COPD exacerbation. Analyzed NIV and MV use during index hospitalization. | 6439 black and 39,672 white patients with COPD exacerbation. | Black patients with COPD exacerbation are more likely to receive MV, either alone or in conjunction with NIV, compared with whites. In adjusted analyses, blacks were more likely than whites to receive mechanical ventilation. The use of MV was higher in black patients in analysis of patients who received NIV. The use of NIV was similar for both races. Higher use of MV among black patients is consistent with other findings of increased use of life-sustaining treatments in end-of-life care. | 2007 HSR&D Annual Meeting Abstracts
Crowley-Matoka, M. | Sociocultural dimensions of provider decision-making in pain management | Arthritis/pain management (outpatient and inpatient) | To describe key patient, provider, and practice-setting factors that influence provider decision-making about the assessment, diagnosis, and treatment of nonmalignant pain; to assess the relationships between and relative importance of identified factors in shaping provider decision-making in nonmalignant pain management; to identify which of these factors are priorities for intervention-targeted work to improve the quality and equity of pain management. | Ethnographic study of provider decision-making in primary care, emergency care, and surgery services in 2 urban VA hospitals | 60–75 health care providers | Not yet available | In data collection phase
Egede, L.E. | Racial/ethnic differences in trust/mistrust and its effect on diabetes outcomes | Diabetes | To assess racial/ethnic differences in trust in physicians and distrust of the health care system among veterans with Type 2 diabetes, and determine the predictive power of trust in physicians and mistrust of the health care system on personal health practices and health outcomes in a prospective cohort of veterans with Type 2 diabetes. | Cohort study that assesses trust in physician and Medical Mistrust Index, and health utilization and diabetes-specific outcomes, from baseline to 12 months. Primary outcome is change in mean socres on trust and mistrust scales by race. 2ndary outcomes are relationship between trust/mistrust and diabetes outcomes (HbA1c, LDL, blood pressure, and use of influenza vaccination). | Veterans with Type 2 diabetes (n=300) | Results not yet available | Ongoing
Ellis, C. and Egede L.E. | Racial/Ethnic Differences in Stroke Awareness among Veterans | Heart/CVD | To examine racial/ethnic differences in recognition of stroke warning signs/symptoms and action to initiate treatment after stroke among veterans. | Data on 36,150 veterans from the 2003 BRFSS. Recognition of 5 warning signs/symptoms and appropriate first action to call 9-1-1 was compared by race/ethnicity. | 36,150 veterans who had a stroke( ?) in 2003 BRFSS | Race was not associated overall with recogniition of individual warning signs/symptoms, but ethnic minorities are less likely to recognize all 5 signs/symptoms and take appropriate action. In adjusted analyses, blacks were less lkely than whites to recognize sudden vision loss. Hispanics and Other races were less likely to recognize all 5 symptoms, and Hispanics and Others were less likely to recognize all 5 symptoms and call 9-1-1 as first action. | 2007 HSR&D Annual Meeting Abstracts
Fagerlin, A. | Impact of plain language prostate cancer decision aid on decision making | Cancer; patient-physician communication; Tests an intervention | To test the effectiveness of a plain language decision aid on prostate cancer patient’s decision making experience and in their interactions with their physician, and to test if there are differences in receipt of active treatment between men with low v. high literacy skills, and between black and white men. | Randomized controlled trial at 4 VAMCs. Intervention compares conventional decision aid vs. a plain language decision aid, given to patient at time of biopsy | Men undergoing a prostate biopsy with expected survival of 5+ years. Target recruitment n=510. | Not yet available | Project to begin this year
Fisher, D. | Fecal occult blood testing completion in a VA population: low and strongly related to race | Preventive/ambulatory care | To assess the proportion of veterans (n=500) who completed the FOBT that was ordered through the primary care clinics at a single VA facility (Durham, NC). | Retrospective medical record review of patient demographics and health history to determine predictors of FOBT card return | 500 veterans aged >50 | 46% of veterans returned their FOBT cards within 9 months of order. Whites were more likely than blacks to return the FOBT card (51% vs. 37%). Race and prior FOBT completion were the strongest predictors of FOBT return. Study did not assess knowledge or perceptions of FOBT screening. | Abstract in HSR&D Publication Brief, February 2007. Expected publication date: February 2007 in Journal of clinical outcomes management.
Frank, D. | Physicians’ Attitudes Regarding Race-Based Therapeutics | Heart/CVD | To determine how physicians interpret and apply the literature on race-based therapies to their medical decision-making for hypertension and congestive heart failure. | Ten focus groups of internal medicine physicians, separate by race (5 groups of white physicinas, 5 groups of black physicians) to determien physicians’ attitudes regarding race-based therapeutics and how physicians currently use Bidil and ACE-inhibitors in their practices. | 90 black and white physicians in 5 US cities | Both black and white physicians were skeptical of the premise of BiDil. Both black and white physicians reported using BiDil to treat their black heart failure patients. Black physicians also reported treating white patients with BiDil despite the lack of trial results. According to both black and white physicians, hypertensive whites respond better to ACE-inhibitors compared to hypertensive blacks. Black physicians were more likely to start a black patient on an ACE-inhibitor as a first line agent for hypertension, while white physicians were less likely to start black patients on an ACE-inhibitor in the absence of a compelling reason such as proteinuria. Both black and white physicians voiced concern about the design of the BiDil trial and the consequences of race-based therapy. | 2007 HSR&D Annual Meeting Abstracts
Golightly, Y.M. | Racial Differences in Treatment Decision-Making among Veterans with Osteoarthritis | Arthritis/pain management | To examine racial differences in patient preferences for involvement in treatment decisions, as well as their perceptions of physicians’ participatory decision-making (PDM) style among veterans with osteoarthritis (OA). | Cross-sectional survey at Durham VAMC | 197 veterans with OA, 30% black, 70% white | There were no racial differences in the proportion of patients who preferred hysician-direct decision-making, or in the mean level of physician PDM. Subjects were racially similar in their perceptions of physicians PDM style and patients' treatment decision-making preferences. | 2006 HSR&D Annual Meeting Abstracts
Gordon, H.S. | Physician-patient communication in patients with chronic heart failure | Heart CVD; patient-physician communication | To assess the relationship of communication to outcomes in patients with chronic heart failure. | Prospective study using surveys, interviews, literacy evaluations. | NR | Not yet available | Ongoing
Groeneveld, P.W. | Racial Differences in Procedures: Are VAMCs with Large Minority Populations Underusing Technology? | Other | To examine racial variation in the use of 10 procedures among VA hospitals | Cohort study; logistic regression model to generate propensity scores for receipt of each procedure based on patient's relevant diagnoses, comorbidities, and age. | All patients admitted to a VAMC in 1998–2003 | VAMCs with larger black populations performed several major procedures (bioprosthetic aortic valve replacement, endoscopic treatment of GI bleeding, colonoscopy, open prostatectomy, total hip replacement, and endoscopic biliary procedures) less frequently among hospitalized veterans, compared with predominantly white VAMCs. Percutaneous coronary interventions were performed more frequently in VAMCs with larger black populations. There were no sig. diffs in the use of implantable cardioverter-defibrillators, dual chamber pacemakers, or laparoscopic appendectomies. | 2006 HSR&D Annual Meeting Abstracts
Groeneveld, PW. | Racial Differences in Expectations of Joint Replacement Outcomes among Veterans with Osteoarthritis | Arthritis/pain management | To assess patients' expectations for pain relief, functional improvement, and psychological well- being after joint replacement surgery. | Cross-sectional survey at 2 VAMCs, using the Hospital for Special Surgery Joint Replacement Expectations Survey | 117 black and 93 white veterans with knee OA, and 50 black and 55 white veterans with hip OA. | Among veterans with moderate-to-severe knee or hip OA, whites have substantially higher expectations for the physical, functional, and psychological benefits of joint replacement surgery. | 2006 HSR&D Annual Meeting Abstracts
Groeneveld, PW. | Racial Differences in Joint Replacement Expectations among Veterans with Osteoarthritis | Arthritis/pain management | To assess patients' expectations for pain relief, functional improvement, and psychological well- being after joint replacement surgery. | Cross-sectional survey at 2 VAMCs, using the Hospital for Special Surgery Joint Replacement Expectations Survey | 459 black and 480 white veterans with OA receiving primary care at 2 VAMCs. | Among potential candidates for joint replacement, blacks have significantly lower expectations for the outcomes of surgery than whites. Favorable expectations of surgical outcomes were highly correlated with increased willingness to consider joint replacement. | 2007 HSR&D Annual Meeting Abstracts Appears to be the same study as in 2006 HSR&D Annual Meeting Abstracts but includes more cumulative subjects.
Heisler, M. | Racial Disparities in Diabetes Care Processes, Outcomes, and Treatment Intensity | Diabetes | To assess whether improvements in diabetes care have reduced previously documented racial disparities in diabetes care processes, intermediate outcomes, and treatment intensity in a random nationwide sample of VA diabetes patients. | Observational study of patients in 51 VA facilities who completed the Ambulatory Care Survey of Healthcare Experiences of Patients in FY 2002, and for whom we had External Peer Review Program data on receipt of diabetes services (A1c, LDl, nephropathy screen, and dilated eye exmaintions), intermediate outcomes (glucose control per A1c, LDL BP control), and medications for certain conditions. | 748 white and 144 black veterans with diabetes | Racial disparities persist in several diabetes care processes and intermediate outcome quality measures, despite improvements in rates of receiving necessary diabetes tests and in outcomes. In FY02, rates of receiving recommended processes and intermediate measures of disease control were significantly higher for both white and black veterans compared with a similar analysis in FY 2000. In FY02 there were no racial differences in receipt of an A1c test or a dilated eye exam among those eligible. Blacks were still less likely than whites to have an LDL checked in teh past 2 year, and to have a nephropathy screen. Race was not a predictor of poor control of LDL, A1c, or blood pressure, in adjusted analyses. | 2006 HSR&D Annual Meeting Abstracts A more recent study with similar methods to Heisler 2003, which analyzed data from FY 1999
Hope, O.A. | Racial Differences in Neurologist Diagnosis and Treatment of Older Veterans with New Epilepsy | Other - epilepsy | To determine the relationship between race, setting of initial diagnosis, and choice of antiepileptic drugs (AED) in older veterans with new onset epilepsy. | Retrospective cohort study, uses national VA and Medicare databases. Setting of diagnosis was classifed as emergency, neurology, hospital, primary care, other specialty, and miscellaneous. Phenobarbital/phenytoin constituted suboptimal AED regimen. | Veterans aged 66+ with a new diagnosis of epilepsy between FY00-FY05, who also received an AED from VA. | Blacks were more likely to receive a suboptimal AED than whites, but this was partially explained by less access to neurology care. Diagnosis in settings other than neurology clinic doubled the odds of receiving a suboptimal AED, and blacks and Hispanics were less likely to have been diagnosed in neurology. | 2007 HSR&D Annual Meeting Abstracts
Ibrahim, S.A. | Knee replacement disparity: a randomized, controlled intervention | Arthritis/pain management; Patient-physician communication; Tests an intervention | 1) To examine the effectiveness of the proposed intervention strategies (decision aid (DA) alone, motivational interviewing (MI) alone or a combined DA+MI)) to improve willingness to consider knee joint replacement when clinically indicated among AA primary care patients. 2) To examine the effectiveness of the proposed intervention strategies on patient expectations of knee joint replacement risks/benefits among AA primary care patients. 3) To examine the effectiveness of the proposed intervention strategies in increasing primary care referrals for surgical evaluation of AA patients with knee OA. 4) To examine the effectiveness of the proposed intervention strategies on increasing the likelihood of receiving knee joint replacment within 12 months. | Randomized controlled trial at 2 VAMCs Intervention compares various intervention strategies to an attention control. Outcomes include patient expectations, willingness, and referral to joint replacement; also doctor- patient communication following intervention or control. | Black primary care patients who meet clinical indications for knee joint replacement; target n=600 | Not yet available | Ongoing
Ibrahim, S.A. | Joint replacement utilization disparity: the role of communication and decision- making | Arthritis/pain management; patient-physician communication | To assess racial differences in the proportion of patients who receive recommendations for joint replacement as a treatment option, who accept treatment recommendation, who are satisfied with the treatment decision, and who undergo joint replacement surgery within six months of the recommendation (secondary outcome); to examine racial differences in patient-provider communication content and processes (style/pattern) regarding knee/hip OA and joint replacement as a treatment option; to examine the association between doctor-patient communication, patient race, and study outcomes. | 3-year cross-sectional observational study | 200 black and 200 white potential candidates for knee or hip joint replacement undergoing evaluation by an orthopedic surgeon | Not yet available | Ongoing
Jha, A.K. | Where Do Black Veterans Receive Hospital Care? Variability in Disparities within the VA Healthcare System | Other | To determine whether mortality rates or racial disparities in outcomes were higher in VA hospitals that disproportionately cared for black veterans. | VA hospitals were ranked by the number of blacks discharged in 2002, and identified hospitals that cumulative cared for 25% and 75% of all black veterans. Analyzed 30-day mortality rates for 6 conditions: pneumonia, AMI, CHF, GI bleeding, hip fracture, and stroke. | Minority-serving hospitals based on number of blacks discharged in 2002 | Hospital care for black veterans is very concentrated, and no variation was found in overall outcomes and racial disparities across hospitals. 9 hospitals cared for 25% of all hospitalized black vets in 2002, and 42 facilities (28% of all VA hospitals) cared for 75% of black veterans. Age- and comorbidity adjusted 30-day mortality did not vary by hospital subgroup for any of the 6 conditions. Results were smilar for black-white differences in mortality across hospitals; blacks with AMI had 20% lower odds of death in minority-serving hospitals, and 18% lower odds of death in non-minority serving hospitals. | 2007 HSR&D Annual Meeting Abstracts
Kilbourne, A.M. | Race, Polypharmacy, and Metabolic Risk Factors in Veterans with Bipolar Disorder | Mental health | To assess racial differences in pharmacotherapy and metabolic risk factors among a cohort of patients with bipolar disorder. | Retrospective cohort study: Continuous Improvement for Veterans in Care-Mood Disorders study on bipolar disorder; multiple logistic regression to determine whether race was independently associated with medication, polypharmacy (receiving a mood stabilizer, atypical antipsychotic, and antidepressant), receipt of mood stabilizer toxicity assay, receipt of cholesterol assay, and medical diagnoses within a 12-month period. | 253 veterans with bipolar disorder, 11% black. | Blacks with bipolar disorder were less likely prescribed mood stabilizers, considered first-line treatment for bipolar disorder. Polypharmacy was common overall (31%). After adjustment for age, gender, living alone, non-VA healthcare, and substance abuse, blacks were less likely than non-blakcs to receive mood stabilizers (OR 0.29, p=0.005), no less likely to receive atypical antipsychotics, cholesterol or mood stabilizer assays, but more likely diagnosed with obesity (OR 2.27, p=0.03) | 2006 HSR&D Annual Meeting Abstracts
Kramer, B. | VA and Indian health Services (IHS): access for American Indian veterans | Preventive/ambulatory care | To describe dual utilization of VA and IHS services among AIAN veterans, including fragmentation or potential overlap of services; to identify organizational and individual factors that impede or facilitate access to care; to generate explicit policy or practice recommendations to improve how VA and IHS work together, including care coordination. | National cross-sectional secondary data analysis of AIAN healthcare utilization in VA and HIS linking administrative data; VA and HIS organizational surveys; interviews with stakeholders; an expert panel | American Indian/Alaska Native veterans | Not yet available | Ongoing
Kressin, N.R. | Functional status outcomes among White and African American cardiac patients in an equal access system | Heart/CVD | To explore whether racial differences in functional outcomes among cardiac patients occur in a setting where difference in access and treatment are minimized. | Prospective cohort study in 5 VAMCs | White and black cardiac patients with positive nuclear imaging studies (n=1022) | There were no racial differences in use of PTCA, but blacks were less likely to undergo CABG. Blacks had more favorable measurements than whites on SF12 physical component, anginal stability, physical limitations, treatment satisfaction, anginal frequency, and disease perceptions. Conclusion: blacks had similar or better functional status outcomes compared with whites. | In press
Kressin, N.R. | Improving Hypertension Control: A Physician Intervention | Preventive care - hypertension management; Tests an intervention | To reduce the proportion of patients with, and reduce racial disparities in, uncontrolled hypertension; to improve patients' medication compliance and decrease racial disparities in antihypertensive therapy; and to improve physicians' communication with patients about medication use. | RCT, facility-based intervention in 3 VAMCs. Physicians in general internal medicine were provided 1 of 3 interventions: 1) computerized reminders, 2) training about patient-centered counseling; or 3) usual care. | Pre-intervention blood pressure readings were obatined from 11,528 white and black hypertensive patients. Followup sample included 556 (70% of baseline). | All study arms showed improved BP control, but improvements in SBP and DBP were greater for whites than blacks. Baseline adherence was 84% among blacks, 88% among whites. This pattern persisted but adherence improved in both groups. Improvements in physician-patient communication varied by race among the sites. | In press
Kressin, N.R. | Hypertensive patients' race, health beliefs, process of care, and medication adherence | Preventive care - hypertension | To explore associations among patient race, self-reported experiences with clinicians, attitudes and beliefs about hypertension, and ultimately medication adherence, among a sample with no racial disparities in BP control, to determine what lessons we could learn from patients and providers in this setting. | Cross-sectional survey of patients previously diagnosed with hypertension from 3 VAMCs | 793 white and black veterans with hypertension, 58% black | Black patients' providers were significantly more active in advising and counseling about hypertension care and medication adherences. Black patients indicated greater knowledge or heightened awareness of the importance of controlling their BP, but there were no race differences in adherence. Worse adherence was associated with having to split pills, believing one's BP continues to be high, and having provider discuss things to do to make it easier to take BP medications. Having more confidence in one's own ability to take BP medications was associated with better adherence. | In press
Kwoh, K. | Reasons for disparities in joint repalcement utilization | Arthritis/pain management; willingness to consider joint replacement | To examine ethnic differences in specific factors related to patients' perceptions of arthritis treatment that may influence willingness to consider joint replacement; and to examine ethnic differences in specific patients' psychosocial characteristics that may influence willingness to consider joint replacement. | Cross-sectional study of patients from primary care clinics of 2 VAMCS | Black and white veterans (total n=980) with symptomatic and radiographic knee or hip OA | Not yet available | Ongoing
Mularski, R.A. | Racial Disparity in Site of Death: African-Americans and Hispanics at Higher Risk for Hospital Death | Rehab/palliative care | To explore racial differences in site of death among veterans. | All veteran deaths in California in fiscal year 2000, linked to national VA patient care database. | 8813 veteran deaths, 77% white, 13% black, 7% Hispanic, 3% other race. | Blacks had a 8% (CI 1–15%) and Hispanics had a 19% (CI 10–29%) higher likelihood of hospital death compared with whites. | 2006 HSR&D Annual Meeting Abstracts
Murdoch, M. | Does PTSD service connection affect disease course and functioning? | Mental health | To examine the effects of receiving/not receiving PTSD disability benefits on long-term outcomes, including PTSD symptom severity, social adjustment, functioning, income, employment, health care utilization and costs, homelessness, and mortality. | Cross-sectional, mailed survey on PTSD symptoms and functioning at two timepoints, Time 1 = 1998–2000; Tiome 2 = 2004–2006. | National sample of 3337 male and female veterans (60% service connected for PTSD, 17% black, 51% female) who applied for VA PTSD disability benefits between 1994–1998. | Analyzes interaction between PTSD SC status with race, but findings do not focus on race. There were no significant race-by-SC status interactions on study outcomes. | Ongoing
Owens, D. | HIV testing of at-risk patients in a large integrated health care system. | HIV | To evaluate whether patients at risk for HIV were being tested, the rationale for testing, and predictors of testing, as well as HIV infection in four large, geographically dispersed VA health care systems. | Retrospective cohort study; VA patient data was determined for HIV-testing during a 5yr period, | 13,991 at-risk (i.e. diagnses of substance abuse, hep B, hep C, all viral hepatitis, or STD) veterans who received VA inpatient or outpatient care over one year. | Of the 13,991 veterans at risk for HIV, only 36% were tested during the 5-yr period. HIV testing was more likely to occur among veterans who were younger, African American, and in veterans who had hepatitis, STDs, or used cocaine or opiates. Study could not determine whether participants had been tested for HIV at non-VA facilities, or whether they had been offered testing and had refused. | Abstract in HSR&D Publication Brief, January 2007. Expected publication date: online January 2007 in JGIM
Partin, M.R. | Assessing and addressing patient colorectal cancer screening barriers | Preventive care - colorectal cancer screening | To estimate the relative effect of patient cognitive, environmental, and background factors on CRC screening behavior; to identify factors that contribute to racial/ethnic disparities in CRC screening behavior; to identify priority population subgroups and factors to target in future interventions; to assess patient values and preferences regarding CRC screening modality options; to estimate stage of readiness to adopt CRC screening in the study population; and to validate measures of CRC knowledge and self-reported screening behavior | Cross-sectional study using mailed survey to national sample | 3,480 male and female veterans aged 50–75 with 1+ primary care visit to a VAMC in 2 years prior | Not yet available | In data collection phase
Rousseau, C.M. | Racial Differences in the Evaluation and Treatment of Hepatitis C: A Retrospective Cohort Study | HIV/HCV | To examine the association between race and hepatitis C treatment among hepatitis C infected patients from all 8 VAMCs in VISN 20. | Retrospective cohort study to determine anti- viral treatment among all hep-C patients in VISN 20 | 4,263 hepatitis C infected veterans in VISN 20, NOS | Blacks were less likely than whites to be evaluated and received anti-viral treatment for hepatitis C. Among those without apparent contraindication to therapy, blacks were significantly less likely than whites to receive anti-viral therapy. Among those whose virus was genotyped, blacks remained significantly less likely to be treated, independent of genotype. Blacks and whites had similar odds of referral to specialty clinics and of undergoing liver biopsy. However, blacks were significantly less likely to have complete laboratory evaluation and viral genotyping. | 2006 HSR&D Annual Meeting Abstracts
Shacter, H.E. | Racial Disparities in Glucose Control: A Qualitative Evaluation of Potential Mechanisms | Diabetes | To elucidate barriers to glucose control that may be unique to African Americans | Focus groups with veterans in 4 categories of glucose control: AA well-controlled; AA poorly controled, whites well controlled, whites poorly controlled. Control defined as HbA1c <8% on two occasions. | Black and white veterans with diabetes | Negative healthcare experiences were uniquely reported by blacks in the poorly-controlled group, with negative codes relating to ppoor access and poor relationships with providers. The well-controlled groups were racially similar in reporting self-care, healthcare, and psychosocial factors as important in controlling glucose. The poorly-controlled groups were racially similar in noting difficulty following a diabetic diet, stress and depression interfering with glucose management, and struggling with temptation. | 2007 HSR&D Annual Meeting Abstracts
Siminoff, L.A. | Ethnic differences - management of patients with ischemic heart disease | Heart/CVD | To examine how health care providers make recommendations, and patients make decisions, about non-invasive v. invasive diagnostic testing (e.g. stress test vs. cardiac cath) and treatment procedures (ie. Medical management v. angioplasty and CABG), specifically to 1) describe patient-physician interactions; 2) outline comparisons between black and white veterans' attitudes toward testing and treatment for CAD; and 3) examine provider views about CAD care; and 4) determine factors in patient-physician interaction that affect decision-making, and the role of ethnicity in these decisions. | Cohort study that follows interaction and decisions of patients and providers from diagnostic testing to treatment; uses audiotaped consultations, and surveys of patients and providers. | 200 black and 200 white patients referred for evaluation for CAD, excludes prior invasive cardiac procedures. | Not yet available | Funding period ended Sept 2003
Spoont, M.R. | Racial and Ethnic Differences in PTSD Treatment Participation | Mental health | To evaluate whether veterans with PTSD initiate mental health treatment and, if they do, receive adequate treatment trials. | Retrospective cohort study using pharmacy data and data from the National Patient Center Database on veterans seen in the VA during 2004–2005 who were diagnosed with PTSD but who had no mental health care in the prior year. | 20,284 veterans with PTSD. | 42% received no MH care 6 months after a PTSD diagnosis. Participation in MH treatment for PTSD varied by race/ethnicity. Native Americans were less likely than all but Asian Americans to receive antidepressants. Hawaiians, blacks, and Hispanics were less likely than whites to receive meds for at least 4 months. Blacks and Hawaiians were more likely than whites to receive any counseling, and blacks were also more likely to receive at least 8 counseling visits. | 2007 HSR&D Annual Meeting Abstracts
Tiet, Q.Q. | Ethnicity and VA Psychiatric and Substance Use Disorder Patients | Mental health/substance abuse | To examine the differences between Caucasian and minority patients on characteristics at treatment initiation, including psychiatric disorders, service needs, readiness for change, initial experience with service providers at intake, and satisfaction of treatment at 6-month followup. | Cohort study of patients entering treatment at 1 of 4 specialty psychiatric or SUD clinics in California and Maryland. Used Diagnostic Interview Schedule and a self-report survey. | 411 veterans at baseline 345 at 6-month followup | Minority patients had more severe psychiatric disorders at treatment initation, incl. schizophrenia and cocaine dependence, but were more likely to express needs for help for both alcohol and drug problems, and had greater readiness to address their substance use problems than did Caucasians. They also reported that their treatment providers liked them less and were less likely to have consensus on the therapeutic tasks with service providers than their Caucasian counterparts. Follow-up data among 260 patients who received psych. treatment in the past 6 months revealed that whites were more satisfied with their psych. treatment than nonwhites. | 2007 HSR&D Annual Meeting Abstracts
Urech, T.H. | Hospital Community Effects on Racial Disparities in Use of Cardiac Procedures | Heart CVD | To determine whether black patients receiving post-acute MI care at VA hospitals located in predominantly black communities are more likely to undergo a post-AMI procedure, compared to black patients receiving care at VA hospitals located in predominantly white areas. | Retrospective cohort study using administrative data on veterans with acute MI at VA cardiac surgery hospitals between 1999–2001. Hospitals were categorized as in a predominantly black or predominantly white area per county-level 2000 Census demographic data. | 11,396 white and 2,116 black post-AMI patientsin 40 VA hospitals | Hospital community effects may contribute to racial disparities in receipt of post-AMI coronary angiography. 22 hospitals were in white areas, 18 in black areas. In adjusted analyses, blacks cared for in black communities were more likely to undergo coronary angiography compared with black patients in hospitals in white communities. White patients cared ofr in black areas were more likely to undergo CA compared with white patients in white areas. The interaction of hospital area and race was not significant for CABG and PCI. Differences in 1-yr mortality were not significant. | 2007 HSR&D Annual Meeting Abstracts
Van Houtven, C.H. | Racial Disparities in Preventable Hospitalization In Community-Dwelling Veterans with Dementia | Other | To explore racial disparities in hospitalizations for ambulatory care sensitive conditions such as diabetes and hypertension, in a vulnerable, rapidly expanding VA population: community- residing veterans with dementia. | Retrospective cohort study, linking inpatient utilization data and the 1998 National Longitudional Cargiver Survey, to identify potential mediators behind racial differences in ACSC hospitalizations | 1813 community-dwelling older male veterans with dementia, and their co- residing female caregivers. | Black veterans with dementia were more likely to be hospitalized for an ACSC, and this disparity was largely explained by differences in enabling factors (e.g. insurance, income, caregiver distress, social support, distance). The effect of caregiver psychological distress differed significantly by race. Black veterans with distressed caregivers were 3.4 times more likely to have an ASCS hospitalization compared to (black?) veterans with non-distressed caregivers, whereas whites with distressed caregivers were less likely to have an ACSC hospitalization. | 2006 HSR&D Annual Meeting Abstracts
Wright, S.M. | Quality of Care and Race in the VA | diabetes; hypertension; Preventive/ambulatory care | To compare the quality of inpatient and outpatient care between blacks and whites in the VA health care system using a well defined set of performance measures addressing disease prevention, common chronic conditions, and acute illness. | Retrospective cross-sectional study of care obtained in FY 2004. Data were obtained from the VA External Peer Review Program. Quality measures were on prevention, chronic disease management, and acute illness management. | 88,965 black and white veterans who obtained VA care during FY 2004, 83% white and 17% black | There were no racial differences for almost all measures that reflect an appropriate process of care. Blacks had significantly lower scores related to hypertension and diabetes control, and immunizations. 27 of 37 quality measures were not statistically different between whites and blacks. Whites had higher adjusted rates (3% or greater) for pneumococcal and influenza screening, as well as 4 diabetes and 2 hypertension measures. | 2006 HSR&D Annual Meeting Abstracts
Yu, W. | End of life care: medical treatments and costs by age, race, and region | Rehab/palliative care | To examine aggressiveness of care by cause of death as well as variations due to age, race, and geographic region, by analyzing medical care costs and utilization patterns of five selected medical treatments in both VA and Medicare facilities during the final 2 years of life of elderly VA patients. | Retrospective analysis using VA and Medicare administrative files to analyze costs and patterns of resource use by type of medical service provided and cause of death | All VA patients who died in FY 2000–2001 (n=149,307). | Black veterans incurred approx. 18% more costs than whites and other minorities in adjusted analyses. Blacks were more likely than whites to use mechanical ventilators and dialysis, but less likely to use cardiac cath. And pulmonary artery monitors. Levels of ICU use were similar. | Funding period ended March 2006; Abstract on HSR&D website
Zeber, J.E. | Ethnicity and the Impact of Higher Medication Copayments among Veterans with Schizophrenia | Mental health | To examine potential ethnic disparities stemming from higher copayments per the 2002 Veterans Health Care Act. | Retrospective cohort study of all veterans with schizophrenia in FY02, followed 20 months pre and post copayment increase to observe changes in prescriptions, health services utilization, and pharmacy costs for individuals with copyment vs. a control group of exempt patients. | 42,853 white, 22,011 black, 6544 Hispanic, and 9228 Other race veterans with schizophrenia. | Minorities used 10–40% fewer pharmacy services (fills, costs) than whites. Following the policy change, whites reduced psychotropic fills 12.5% with little change in hospital use. Minorities dropped psychotropic prescriptiosn 14.5% – 26.8% while increasing psychiatric admission risks 3.6%–8.5%. Hispanics ranked highest on both changes. No outpatient utilization differences were observed. Ethnic minorities, Hispanics in particular appeared more sensitive to drug costs and refill decisions for these medications, and experienced substantially elevated admission risks associated with lower cost-related adherence, compared with whites. | 2006 HSR&D Annual Meeting Abstracts
Zeber, J.E. (see Kilbourne, A.M.) | Ethnicity, Perceptions of Therapeutic Alliance, and Adherence in Patients with Bipolar Disorder | Mental health | To examine the association between perceptions of the healthcare environment and adherence among veterans with bipolar disorder. | Cohort study; patients recruited from the Continuous Improvement for Veterans in Care-Mood Disorders study (same sample as Kilbourne, A.M.) | 253 veterans with bipolar disorder, 11% black. | Fewer minority veterans than whites had good medication adherence, but no ethnic differences were noted in perceptions of working alliance. Favorable perceptions of trust and satisfaction with bipolar treatment existed across all ethnic group. | 2006 HSR&D Annual Meeting Abstracts

Abbreviations
ACE-I: Angiotensin-converting enzyme inhibitors
ACQUIP: Ambulatory Care Quality Improvement Project
AMI: Acute myocardial infarction
ARB: Angiotensin II Receptor Blockers
AVR: Bioprosthetic aortic valve replacement (AVR)
CA: Carotid angiography
CABG: Coronary artery bypass graft surgery
CAD: Coronary artery disease
CC: Cardiac catheterization
CEA: Carotid endarterectomy
CHF: Congestive heart failure
COX-2: Cyclooxygenase-2 inhibitors
CVD: Cardiovascular disease
DCP: Dual-chambered pacemaker
GDS: Geriatric depression scale
ICD: Implanted cardioverter/defibrillator
K/L: Kellgren-Lawrence scoring system for radiographic evaluation
NPCD: National Patient Care Database
NR: Not reported
NS: P-value not significant
NSAIDs: Non-steroidal anti-inflammatory drugs
NYHA: New York Heart Association
OA: Osteoarthritis
OLS: Ordinary least squares model
OPC: Outpatient clinic file
PBM: Pharmacy benefits management file
PCI: Percutaneous coronary intervention
PDM: Participatory decision making
PTCA: Percutaneous transluminal coronary angioplasty
PTF: Inpatient patient treatment file
RA: Rheumatoid arthritis
SF-36: Medical Outcome Study Short Form Health Survey
TIA: Transient ischemic attack
TKA: Total Knee Arthroplasty
VHD: Valvular heart disease
WOMAC: Western Ontario McMaster Universities Osteoarthritis Index