# INCLUSION/EXCLUSION CRITERIA

## Inclusion/Exclusion Codes for abstracts and full-text articles

Code | Include/Exclude | Reason
I1 | Include | Published studies that:; a. Are conducted within VHA or with VA beneficiaries AND; b. Report data by patient race and/or ethnicity AND; c. Report data on; i. Utilization of health care services; ii. Quality of health care services; 1. Process-of-care measures (e.g., use of appropriate screening tests); 2. Outcome measures used by VHA as quality metrics (e.g., blood pressure control); 3. Patient evaluations of care (e.g., patient satisfaction); 4. Direct observations of care (e.g., communication patterns); iii. Potential mediators of racial/ethnic disparities in utilization or quality; 1. System level mediators (e.g., distribution of services); 2. Provider level mediators (e.g., racial bias); 3. Patient level mediators (e.g., trust); 4. Patient-provider level mediators (e.g., communication)
I2 | Include | Systematic review or meta-analysis of studies meeting I1
I3 | Include | Unpublished research meeting I1
I4 | Include | Background or review articles relevant to racial disparities in VHA (for review of reference lists)
I5 | Include | Other (specify)
X1 | Exclude | Outcomes that are not clear indicators of utilization or quality of care or potential mediators of disparities in utilization/quality (e.g., reports on health outcomes that are not clearly markers of health care quality)
X2 | Exclude | Non-U.S.VHA setting and non-VA population
X3 | Exclude | Data not stratified by patient race and/or ethnicity
X4 | Exclude | No original data
X5 | Exclude | Non-English language, no abstract
X6 | Exclude | Non-human, animal
X7 | Exclude | Other (specify) e.g. NRF