# SEARCH STRATEGY

Search terms and MeSH headings:

((VA [tw] OR veteran* [tw]) OR (United States Department of Veterans Affairs [mh] OR veterans [mh] OR veterans hospitals [mh])) AND ((ethnic* [tw] OR race [tw] OR racial [tw] OR disparity [tw] OR disparities [tw] OR blacks [tw] OR black [tw] OR Hispanic* [tw]) OR (population groups [mh] OR race relations [mh]))

Databases searched: Medline via PubMed, HealthSTAR, and Health Services Research Projects (HSRProj). The HSRProj database identified ongoing and completed VA research projects, and indicated whether these studies had been published.

Dates searched: 1966-October 9, 2006.

Automatic updates: The search strategy is saved in the PubMed database to provide weekly updates on new publications.