# SUMMARY AND DISCUSSION

For KQ1, we only found studies addressing the responsiveness of the PHQ-9 and PHQ-2. In these few studies, there was a consistent association between PHQ-9 change scores and interview-based assessments of clinical status. The single study comparing the PHQ-9 and PHQ-2 showed comparable responsiveness. One study[34] included VA settings and is directly applicable to VA populations. In this study, a direct comparison of PHQ-9 to a longer questionnaire showed comparable responsiveness. Another study conducted relevant subgroup analyses with the German language version of the PHQ-9 and found similar responsiveness for important subgroups including men and women, and patients with comorbid medical conditions. A single study examined the minimum clinically important difference (MCID) and conservatively estimated this value as a 5 point change. This finding is consistent with other studies that use cross-sectional analyses to infer the MCID.[41] In summary, the PHQ-9 is the best validated instrument for identifying depressed patients in primary care [14–16]and for detecting clinically important response to treatment.

A recent literature synthesis [8] identified baseline and follow-up assessment of depression symptoms with a standardized scale as key features of effective depression care. The PHQ-9 appears well suited for this purpose and has been used in large VA evaluations of depression care.[45] Based on a single study conducted in Germany, the PHQ-2 appears responsive to change but only tracks two criterion symptoms and does not include an assessment of suicidal ideation. Based on this limited data and concerns about inadequate clinical data, the PHQ-2 alone cannot be recommended to monitor treatment response for clinical purposes. It may be useful for research studies when very brief instruments are needed. Our review was based in part on the assumption that questionnaires need to be brief to allow for both self-administration and interview administration in person or by telephone as is often done in integrated mental health-primary care models. Other, longer instruments may be preferred if the data collection burden can be eased through interactive voice response, web-based applications or scanable forms and the instrument has superior clinical content, better responsiveness or a better defined minimum clinically important difference. In addition, the response burden would need to be acceptable to patients.

Qualitative studies show that patients favor questionnaires to measure depression severity but general practitioners in the UK were cautious about the validity and utility of these measures and skeptical about the motives behind their introduction.[46] General practitioners specifically valued clinical judgment more than objective assessment. Practitioners were aware of the potential for manipulation of indicators for economic reasons. In the U.S.A., the PHQ-9 has been successfully implemented into primary care and psychiatric practices as part of quality improvement studies[47] and pragmatic clinical trials.[48, 49] These findings suggest that successful implementation of the PHQ-9 (or any other measure) will need to address attitudinal barriers and provide logistical support to integrate PHQ-9 administration into routine clinical processes.

For KQ2, the high quality systematic review[35] and 2 of the most recent relevant RCT’s provide moderately strong evidence that continued antidepressant treatment decreases the risk of subsequent relapse for patients with MDD who achieve partial- or full-remission. The magnitude of risk reduction was similar for shorter- and longer-term trials and maintained for up to 2 years. The number needed to treat to prevent one relapse over a mean time of 8 or 16 months was 5. However, these trials do not directly answer our question about the minimum duration of continued antidepressant treatment since they report the average risk reduction over these time periods. In the single trial randomizing patients to differing durations of continuation treatment, the risk reduction was similar for 14 and 38 weeks but declined by 50 weeks. More studies utilizing this design in patients with various risks of relapse would better address the issue of minimum duration.

At the individual patient level, the decision for how long to continue antidepressant treatment should be based on effectiveness, adverse effects and patient preferences. These studies show clinically important risk reduction and adverse event rates similar to or slightly lower than acute phase treatment studies. A comprehensive review of adverse effects was beyond the scope of this study, but a careful evaluation of long-term adverse effects would be important to an accurate assessment of net benefit. antidepressants may increase the risk of osteoporosis[12, 13] or gastrointestinal bleeding in patients with concurrent non-steroidal anti-inflammatory drugs or low dose aspirin. Given the high rates of indicated aspirin use in the veteran population, a careful weighing of benefits and risks is needed and will depend in part on the patient’s baseline risk of relapse or recurrence. As baseline risk of relapse increases, the absolute benefit increases. Since these studies appeared to enroll patients primarily from mental health settings, these patients may have been at higher risk than the average primary care patient with major depression. However two factors argue for applicability to primary care. First, the trials excluded patients with concurrent psychiatric conditions that may have increased the risk of relapse. Second, the large primary care based study by Unutzer et al.[50] included VA settings and found that almost three-quarters of patients with major depression had at least two prior episodes, a strong predictor of relapse risk. The current APA guidelines recommend at least 16–20 weeks of continuation treatment after remission is achieved and a judgment about maintenance treatment that is individually tailored to the patient. Other guidelines recommend longer treatment in patients at elevated risk. A key point and one that may require increased attention in primary care is need for a careful assessment of relapse risk when making the decision about continuing antidepressants beyond the acute and continuation phase treatment.

## LIMITATIONS

Our review has a number of potential limitations. First, there are no validated search strategies to identify the literature for KQ1, increasing the risk that we may have missed relevant studies. Second, there were insufficient studies to do quantitative evaluations for publication bias or statistical heterogeneity. In addition, these types of studies are not typically included in clinical trials registries, further limiting our ability to detect publication bias. Third, we did not include studies that examined simple change in depression scores without a comparator to an interview-based measure of response. These studies could provide some, although less convincing evidence for responsiveness. Finally, the same author (Lowe) used three separate datasets from different study populations to conduct the relevant analyses. Replication by multiple investigators could increase confidence in the results.

For KQ2, the search strategy did not include foreign-language or articles published outside the Medline^®^ database, potentially excluding relevant findings. However, the systematic review that was identified was recent, high quality, and addressed heterogeneity and publication bias. The systematic review looked to compare relapse rates for placebo and antidepressants during continuation and maintenance phase, but did not address directly the optimal duration of treatment. The two higher quality RCT’s we identified found results consistent with the systematic review. Finally, we did not address first-generation antidepressants.

## Conclusions

Table 7 Summary of Systematic Evidence Review by Key Question

KQ | Key Question | Type of Evidence | Quality of Evidence | Comments
1 | Responsiveness of depression questionnaires | Observational | Moderate | PHQ-9 is responsive to change (mean change −11.2 to −6.7 for responders; standardized response mean −2.15 to −1.4)
2 | Minimum duration of continued antidepressant treatment in patients achieving remission | RCT’s | Moderate | Continued antidepressant treatment decreases the risk of relapse by 0.54 to 0.56 for up to two years (Number needed to treat = 5)