# RESULTS

## LITERATURE FLOW

For KQ1, the combined library contained 673 citations, of which we reviewed 82 articles at the full-text level (Figure 2.). Of the 82 articles, 4 studies met eligibility criteria [31–34] but two citations [31, 32] were derived from the same study population leaving 3 unique studies. For KQ2, the combined library for systematic reviews contained 106 citations, of which we reviewed 9 articles at the full-text level (Figure 3). Of the 9 articles, we included the most recent, high quality review meeting eligibility criteria. [35] To identify new studies since the eligible systematic review was complete, we searched for relevant RCT’s from January 2007 to present. This search identified 48 citations, of which we reviewed 6 articles at the full-text level (Figure 4.). Of the 6 articles, 3 studies with 4 comparisons met eligibility criteria.[36–39]

Figure 2 Key Question #1 Literature Flow

Figure 3 Key Question #2 Literature Flow

Figure 4 Key Question #2 Randomized Control Trials Literature Flow

## KEY QUESTION 1. In patients with major depressive disorder treated in primary care settings, what assessment tools are responsive to change?

### STUDIES EVALUATING RESPONSIVENESS OF DEPRESSION QUESTIONNAIRES

We identified 3 studies that compared change scores for an eligible depression questionnaire to an interview based assessment of depression severity. All three studies used the PHQ-9 and one of these completed a separate analysis of the PHQ-2. Two studies were conducted in Germany, using German language versions of the questionnaire. One study was a secondary analysis from a multi-center randomized trial of care management in older adults and included three VA sites. Key features of the studies are summarized in Table 1 and study details are contained in Appendix E.

Table 1 Characteristics of Studies Evaluating Responsiveness of the PHQ-9

Study | Lowe 2004[34] | Lowe 2006[33] | Lowe 2004[32] and Lowe 2005[31]
N | 434 | 1788 | 108
Primary care | Yes | Mixed | Mixed
VA settings | Yes | No | No
Mean age (SD) | 70.9 (7.3) | 50.3 (14.7) | 41.1 (14.2) to 42.8 (12.1)
Men | 160 (36%) | 594 (33.2%) | 34 (31.5%)
Major depressive disorder | 317 (73%) | 757 (42.3%) | 55 (51%)
Questionnaire | PHQ-9 (English) | PHQ-9 (German) | PHQ-9 (German)
Comparator | Structured Clinical Interview for DSM-IV | Clinical Global Impression | Structured Clinical Interview for DSM-IV
Quality | Good | Fair | Fair

The responsiveness, or sensitivity to change of an instrument describes its ability to accurately detect clinically meaningful change when it occurs. There is no consensus on the best measure for describing responsiveness but three common methods are used in the studies reviewed: effect size, standardized response mean and responsiveness index.

- Effect size: Mean (time 2)-Mean (time1)/Standard deviation (time 1) [40]
- Standardized response mean: Mean (time 2)-Mean (time1)/Standard deviation of score changes [18]
- Responsiveness index: Mean (time 2)-Mean (time1)/Standard deviation in unchanged subjects [19, 20]

The good quality study by Lowe et al [34] is the most applicable to Veterans. It evaluated the responsiveness of the PHQ-9 and Symptom Checklist-20 (SCL) in older adults enrolled in a randomized trial comparing collaborative care to usual care. The PHQ-9 was self-administered or given by telephone interview. The study was conducted in 18 primary care sites, three that were VA. Participants were age ≥ 60 years old, had a mean of 3.8 ± 2.0 chronic diseases and had a research-based diagnosis of major depressive disorder or dysthymia. Among intervention patients, 71% had ≥ 2 prior episodes of depression, 35% screened positive for cognitive impairment and 28% screened positive for anxiety symptoms. Important exclusion criteria were: severe cognitive impairment, CAGE ≥ 2 or history of bipolar disorder or psychosis. The analysis was limited to patients in the intervention arm who had the depression questionnaires, the interview-based Structured Clinical Interview for DSM-IV and clinical assessment within 2 weeks of each other at each scheduled assessment: baseline, 3- and 6-month follow-up. Of the 906 intervention patients, 434 (47.9%) had complete assessments. Study strengths were: independent, blind comparison of the questionnaires and interview-based assessments, an adequate criterion standard and appropriate analysis. A weakness was that only 48% of patients enrolled were analyzed, but the study sample was similar to the intervention group overall except for a smaller proportion of ethnic minorities. The mean change and standardized response mean (SRM) for the PHQ-9 and SLC-20 are in Table 2.

Table 2 Responsiveness in Patients with Major Depressive Disorder or Dysthymia (n=434)

| Baseline | 3 Month Change | | 6 Month Change
Instrument | Mean (SD) | Mean (SD) | SRM (95% CI) | Mean (SD) | SRM (95% CI)
PHQ-9, range 0–27 | 13.6 (5.4) | −7.5 (5.8) | −1.3 (−1.4 to −1.2) | −8.0 (6.1) | −1.3 (−1.4 to −1.2)
SCL-20, range 0–4 | 1.7 (0.6) | −0.6 (0.7) | −0.9 (−1.0 to −0.8) | −0.8 (0.7) | −1.2 (−1.4 to −1.1)

At 3 months, the PHQ-9 was more responsive than the longer SCL-20; at 6-months the responsiveness was not significantly different. The results were unchanged when the analysis was restricted to subjects with MDD. In a secondary analysis, the SCID was used to categorize treatment response for the 317 patients with MDD as persistent MDD (≥ 5 criterion symptoms), partial remission (1–4 criterion symptoms) or full remission (no criterion symptoms). Using this classification, the mean change and standardized response mean at six months were as displayed in Table 3.

Table 3 Responsiveness Characteristics in Patients with Major Depressive Disorder at Six Month Follow-up (n=317)

| PHQ-9 | | SCL-20
SCID category | Mean change (SD) | Standardized response mean | Mean change (SD) | Standardized response mean
Persistent MDD | −5.6 (6.6) | −0.8 | −0.3 (0.7) | −0.4
Partial remission | −8.4 (6.1) | −1.4 | −0.9 (0.6) | −1.5
Full remission | −9.8 (5.9) | −1.7 | −1.3 (0.6) | −2.2

For both instruments, an independent assessment of clinical improvement is associated with greater reductions in symptom scores. Finally, the authors determined the minimum clinically important difference (MCID) in a subset of 82 patients who had the PHQ-9 administered twice, exactly 7 days apart at the 6-month follow-up. The MCID was calculated as the standard error of measurement * 1.96. A sensitivity analysis showed the MCID ranged from 2.59 to 4.78 consistent with prior recommendations based on cross-sectional studies.[41]

The studies by Lowe et al conducted in Germany and using a German-language version of the PHQ-9 are less applicable to VA settings. [31–33] German language versions of the PHQ-9 may theoretically perform differently from the English language version. The larger study [33] enrolled 1878 patients and was conducted in the context of an open-label, post-marketing surveillance trial of sertraline. Patients were adults with major, minor or other depressive disorders beginning a course of the antidepressant sertraline. The PHQ-9 was compared to the Clinical Global Impression (CGI) at 3 months. Patients with a CGI of 1 (very much improved) or 2 (much improved) were classified as responders (n=1552, 86.8%). Study strengths were: a follow-up rate of 95%, and appropriate analysis and administration of the PHQ-9 blind to the CGI results. Study weaknesses were: the CGI criterion standard was applied with knowledge of the PHQ-9 results and almost 50% the raters were non-mental health professionals with a single training session on using the CGI rating scale. In addition the study team included a biostatistician from Pfizer and Pfizer funded the analysis by Lowe et al and the PHQ-9 development suggesting a potential conflict of interest. The mean change scores and standardized response means are shown for CGI responders and non-responders (Table 4).

Table 4 Responsiveness Characteristics at Three Month Follow-up (n=1788)

| PHQ-9 (German Language Version)
CGI category | Mean change (95% CI) | Standardized response mean
Non-responder | −4.42 (−5.0 to −3.84) | −1.00
Responder | −11.15 (−11.41 to −10.8) | −2.15

Subgroup analyses were conducted comparing responsiveness by gender, age groups, depression diagnosis, and presence of comorbid physical illness. Standardized response means were similar for these subgroups. Because this study was an open label trial, the study population may be more representative of typical patients initiating antidepressants than those recruited into a randomized trial.

The second German-language evaluation of the PHQ-9 followed a cohort of 167 patients with major depressive disorder (n=55), other depressive disorder (n=53) or no depressive disorder (n=59).[31, 32] Only the first two groups with depressive disorders are relevant to our study question and our discussion is limited to these groups. At 12-months, PHQ-9 changes scores were compared to clinical status as determined by the Structured Clinical Interview for DSM-IV (SCID). Improved status included patients who transitioned from major depressive disorder to other- or no depressive disorder and patients with other depressive disorder who transitioned to no depressive disorder. Worse clinical status included those who transitioned from no depressive disorder to major depressive disorder. Study strengths include a follow-up rate > 80%, appropriate analysis and an adequate criterion standard administered by trained raters with excellent inter-rater reliability. Limitations are lack of an independent, blind comparison between the PHQ-9 and SCID at 12-month follow-up. Results are given for both the PHQ-9 and for its first 2 items (PHQ-2) (Table 5).

Table 5 Responsiveness Characteristics at Twelve Month Follow-up (n=108)

| PHQ-9 | | | PHQ-2
SCID category | Mean change (SD) | Effect size | Standardized response mean | Mean change (SD) | Effect size | Standardized response mean
Worse | 3.25 (4.3) | 0.62 | 0.75 | 1.0 (2.0) | 0.6 | 0.5
Unchanged
MDD | 0.24 (4.2) | 0.05 | 0.06 | 0.4 (1.3) | 0.3 | 0.3
Other Depression | −1.96 (5.28) | −0.38 | −0.37 | −0.7 (2.2) | −0.5 | −0.3
Improved | −6.7 (4.91) | −1.33 | −1.42 | −2.3 (2.1) | −1.4 | −1.1

Across the three studies, the standardized response mean ranged from −1.0 to 0.5 for patients who were unchanged or worse, and −2.15 to −1.4 for those who responded or remitted. Mean changes in PHQ-9 showed greater variability: −5.6 to 3.25 for non-responders and −11.15 to −6.7 for those who responded or remitted. The three studies vary on a number important design factors that may explain some of the observed heterogeneity. Effect sizes were calculated over a range of follow-up from 3 to 12 months. Study samples differed in ways that could affect responsiveness, including the proportion with major depressive disorder, the mean age and proportion male. The PHQ-9 was administered in English and German languages. The interview-based comparator differed and definitions of response varied across studies. Finally, study quality differed importantly. Despite these sources of potential variability, the overall results were consistent across studies. Greater clinical improvement as determined by an interview based severity measure was associated with greater improvement on the PHQ-9. Using the GRADE criteria that incorporates study design, consistency and precision of results, publication bias and directness, we judge the body of evidence as moderate quality, downgrading for limitations in study design.

## KEY QUESTION 2. In primary care patients with major depressive disorder who remit with antidepressant medication, what is the minimum treatment duration to decrease the risk of relapse or recurrence?

The selected systematic review[35] evaluated 23 fair quality RCT’s that compared a second-generation antidepressant to placebo in patients who achieved partial- or full remission after acute phase treatment. Using the quality assessment instrument described in Appendix D, this systematic review met all quality criteria. Included studies generally enrolled patients with a criteria-based diagnosis of major depressive disorder and excluded patients with concurrent psychiatric illness (e.g. substance abuse or anxiety disorder) or severe chronic medical conditions. None of the studies described a VA recruitment site. Four studies recruited patients from primary care and psychiatry outpatient clinics, 12 were conducted in unspecified outpatient clinics; the remaining seven settings were not described. Studies used a randomized discontinuation design, randomizing responders to continued antidepressant or placebo. In all trials, antidepressants were used in the acute phase of treatment; none described adjunctive treatment with non-pharmacological treatment. All but two[42, 43] of the 23 RCT’s continued the same antidepressant or antidepressants at the same dose from acute phase treatment to continuation and maintenance phases. Only studies evaluating second-generation antidepressants were included; a list of these is available in the evidence table (Appendix E). The primary outcomes were relapse and recurrence rates during continuation and maintenance phases. Relapse was generally defined as a Hamilton Depression Rating Scale score exceeding a specified severity level. Secondary outcomes were adverse event rates and treatment discontinuation due to adverse events. A separate analysis included 4 RCT’s that compared antidepressants to each other with regards to rates of relapse after remission; this analysis is not included for further discussion here because it does not relate directly to KQ2.

Because the RCT’s defined their continuation and maintenance phases differently, the authors of the systematic review stratified the studies by treatment duration: less than 1 year after acute phase treatment remission (continuation) and 1 year or more after acute phase treatment remission (maintenance). Results stratified by continuation and maintenance phase treatment are summarized in Table 6. The unadjusted frequency of relapse for continuation phase (12 studies) was 22% for active treatment and 42% for placebo. Heterogeneity among these trials was moderate (I^2^ = 47%). The unadjusted frequency of recurrence for maintenance phase (11 studies) was similar to continuation phase treatment: 26% for active treatment and 48% placebo. Heterogeneity for these longer duration studies was also moderate (I^2^=30%). Tests for publication bias were not statistically significant for either group of studies. Meta-regression analyses were conducted to evaluate heterogeneity. The duration of open-label treatment before random assignment of responders, the length of the post-randomization phase and type of second-generation antidepressant were not associated with the estimate of effect. The authors concluded that their results provide consistent evidence in favor of antidepressant treatment over placebo in both continuation and maintenance phases.

Table 6 Systematic Review -Summary of findings

| Unadjusted frequency of relapse/recurrence | Pooled relative risk of relapse/recurrence | Number needed to treat to prevent 1 additional relapse/recurrence
Continuation (<1yr of ongoing treatment) | 22% antidepressant 42% placebo | 0.54 (95% CI 0.46 to 0.62) | 5 (95% CI 4 to 6) over a mean time of 8 months
Maintenance (≥1yr ongoing treatment) | 26% antidepressant 48% placebo | 0.56 (95% CI 0.48 to 0.66) | 5 (95% CI 4 to 6) over a mean time of 16 months

Adverse events were reported incompletely. The most common adverse events documented in continuation and maintenance phases were headache (weighted mean incidence 15.5%) and nausea (7.4%). Based on data pooled from 18 of the RCT’s, loss to follow up due to adverse events was not statistically significantly different between antidepressant and placebo (relative risk=1.42, CI = 0.92 to 2.20).

The primary limitation of this review is the lack of studies designed to specifically answer our study question – the minimum duration of continued treatment to prevent relapse or recurrence. Only one study[44] randomized patients in remission to varying durations (14, 30 or 50 weeks) of continuation phase antidepressant or placebo. Relapse rates were significantly lower for patients on active treatment at 14 weeks (26% vs. 49%), and 38 weeks (9% vs. 23%) but not at 50 weeks (11% vs. 16%). Only 62 patients were randomized to 50 weeks treatment and the finding of no benefit is inconsistent with the overall body of evidence. A second limitation is incomplete descriptions of the study setting, recruitment approach and patient clinical and demographic characteristics. Careful descriptions of study populations, including risk factors for relapse would help decision makers apply these data. If patients included were at particularly high risk, then the estimates of baseline risk (from the placebo control groups) would not apply to patients with uncomplicated depression at low risk for relapse. Thus, the absolute benefit and number needed to treat (NNT) could be overstated.

Our search for additional RCT’s identified three eligible studies published since the systematic review. The Prevention of Recurrent Episodes of Depression with Venlafaxine for Two Years (PREVENT) was a multi-phase, double-blind, placebo-controlled study of patients with recurrent MDD. Analyses from two phases of this larger study[37, 39] were relevant to KQ2. In the first phase, [37] participants who maintained a satisfactory response or clinical remission after acute phase and six months continuation phase treatment were randomized to 12-month maintenance treatment with venlafaxine ER or placebo. Venlafaxine ER was associated with a statistically significantly lower recurrence rate at 12-month follow-up (23.1% vs. 42.0%).The study had significantly higher loss to follow-up in the placebo group, which may have underestimated the difference between relapse rates. In the second phase[39] patients maintaining response at 12 months in phase 1 were re-randomized into a second 12 month course of venlafaxine ER or placebo. Failure to maintain response was defined as an increase in maintenance dose to 300mg/day or recurrence (HDRS-17 score > 12 and reduction of <= 50% from acute-phase baseline). Kaplan-Meier probability estimates for maintaining response across the combined 2 years of maintenance therapy were 67% for venlafaxine ER <= 225 mg/day and 41% for placebo (P = 0.007). This second report from the PREVENT study was of fair quality and did not report an analysis of patients lost to follow up in placebo or antidepressant groups, thus limiting applicability of its conclusions.

A good quality RCT[38] reported the results of a 24 week randomized controlled trial of escitalopram (10–20 mg per day) versus placebo in older adults who responded to a 12 week trial of open label escitalopram for treatment of a major depressive episode. The proportion of patients who relapsed within 24 weeks was significantly higher in the placebo group (33%; 50 patients) than in the escitalopram group (9%; 13 patients), (p<0.001). A small, fair quality RCT[36] reported the one-year follow up of 106 patients who had responded to 16 weeks of treatment with paroxetine, cognitive therapy, or behavioral activation. Of the 49 responders allocated randomly to either continued paroxetine treatment (n=28) or to placebo (n=21), relapse rates were 53% for antidepressant medication and 59% for placebo.

These additional studies support the findings of the systematic review. Continued treatment for 1 to 2 years after achieving partial- or full-remission with second-generation antidepressants decreases the risk of relapse or recurrence by almost 50%. Based on RCT’s with some important limitations, generally consistent results and a precise estimate of effect, we grade the overall strength of evidence for this finding is moderate.