# FUTURE RESEARCH

Although moderately strong evidence shows the PHQ-9 is sensitive to change, studies that use receiver operating characteristic analysis to determine how well specific change scores classify patients into improved and unchanged or worse would be useful. These studies could help establish the minimum clinically important difference, which currently is based on limited data. Since data are limited in important subgroups (e.g., medical comorbidity, psychiatric comorbidity), studies evaluating responsiveness in key subgroups could also strengthen validity. Brief depression questionnaires, such as the PHQ-9, could be used in VA for performance measurement. Performance indicators could include: baseline administration at diagnosis (as an indicator of careful diagnostic assessment), administration longitudinally (as an indicator of careful follow-up), change scores or proportion achieving clinical response, or linked indicators that examine changes in treatment matched to changes in severity scores. Studies to examine the feasibility, acceptability to patients and clinicians, validity and impact on process of care and patient outcomes could help inform policy. If undertaken, these studies should include provisions for evaluating any unexpected consequences of introducing these measures into routine practice.

Although it is clear that continued antidepressant treatment beyond the acute phase decreases relapse, the optimal duration of treatment remains uncertain. Some clinical guidelines recommend that maintenance treatment duration should be customized based on risk factors for relapse, but the randomized trials we reviewed did not examine a risk factor based strategy. Future studies should carefully describe patient characteristics, such as number of prior depressive episodes that may predict relapse. These data would aid clinicians in applying these data and could help explain heterogeneity in treatment effects. Most importantly, analysis of a timeline for patients during continuation and maintenance phase would be most informative, documenting critical periods of increased relapse if they exist and measuring the balance between adverse effects and beneficial effects as patients stay on the antidepressant versus placebo treatment. It would also be informative to compare the different second-generation antidepressants, as well as compare first and second generation antidepressants.