# BACKGROUND

## DEPRESSION QUESTIONNAIRES

A prior systematic review identified eleven self-administered depression questionnaires that had been evaluated in primary care settings; most have been evaluated in VA settings.[14] Questionnaires ranged from 1 to 30 items; 7 had versions of ≤ 10 items. Response formats included “yes/no,” frequency ratings, and statements of symptom severity. Scores ranged from as brief as 0 to 1 for a single item, “yes/no” questionnaire to 0–100. All instruments could be self-administered in < 5 minutes but interview administration varied more substantially due to differences in length and response format. Six of the instruments were considered useful for monitoring severity or response but this judgment was based on scale characteristics rather than empirical data. A recent update of identified 3 additional questionnaires and new studies for existing questionnaires.[15] Brief, 2–9-item questionnaires compared comparably to longer questionnaires.[16] The review concluded that the Patient Health Questionnaire-9 (PHQ-9) had better performance characteristics and gave more information for depression diagnosis than other instruments. A recent National Heart, Lung, and Blood Institute working group recommended the PHQ-2 (whose items are contained within the PHQ-9) to screen for trial entry and recommended the interviewer-rated Hamilton Depression Rating Scale (HDRS) to assess outcomes. Interviewer-rated instruments, such as the Hamilton, are the reference standard for evaluating depression severity but require greater expertise, training and administration time than self-administered questionnaires and for this reason are not considered feasible for clinical purposes in the primary care setting.[17] Given the large number of validated questionnaires, we focused this review on brief instruments that may be more acceptable to clinicians and patients.

Brief Depression Questionnaires Validated in Primary Care Settings

Questionnaire | Items | Response format | Literacy level
BDI Fast Screen | 7 | 4 Statements of symptom severity | Easy
CES-D | 10 | 4 Frequency ratings: “less than 1d” to “most or all (5–7d)” | Easy
DEPS | 10 | 4 Frequency ratings: “not at all” to “extremely)” | Average
GDS | 15 | Yes or no | Easy
PHQ-9 | 9 | 4 Frequency ratings: “not at all” to “nearly every day” | Average
SDDS-PC | 5 | Yes or no | Easy

Abbreviations: BDI, Beck Depression Inventory; CES-D, Center for epidemiologic Studies Depression Screen; DEPS, Depression Scale; GDS, Geriatric Depression Scale; PHQ-9, Patient Health Questionnaire-9; SDDS-PC, Symptom-Driven Diagnostic System for Primary Care

## MEASURING RESPONSIVENESS TO CHANGE

Health status measures are typically evaluated for reliability and validity. A third characteristic, important for detecting clinically important change over time, is the measure’s responsiveness. Responsiveness is determined by two properties: reproducibility, and the ability to register changes in scores when a patient’s symptom status shows clinically important improvement or deterioration. Although there is no universally recommended measure of responsiveness, most indices rely on calculation of an effect size. The effect size is a unit-free index that uses the mean change score in the numerator and a measure of variability in the denominator. The Standardized Response Mean[18] and the Responsiveness Index[19, 20] are particularly useful approaches to calculating effect sizes for this application because they incorporate information about the response variance into the denominator. Deyo and others argue that the issue is not just sensitivity to change but the ability to discriminate between those who improve and those who do not.[19, 21] Receiver operating characteristic curves are proposed as an approach for describing how well various changes in scale scores can distinguish between improved and unimproved patients. This approach requires a valid reference standard to make these clinical classifications.

## RISK OF RELAPSE OR RECURRENCE

The goal of depression treatment is to help patients achieve full recovery, defined as a sustained period where no or minimal symptoms exist and full functional status has returned. Operationally, this has been defined as a Hamilton Depression Rating Scale score of ≤ 7. [22] Patients with major depression who remit with antidepressant medication have at least a 50% lifetime risk of recurrence. Patients at particularly high risk include those with ≥ 2 prior major depressive episodes, chronic major depression, a family history of bipolar disorder and more severe depression. The 1993 Agency for Health Care Policy and Research clinical guideline for depression used epidemiological data to propose three treatment phases: acute, continuation and maintenance (Figure 1).[23] Acute phase treatment describes the period of initial treatment until remission is achieved, continuation phase extends treatment for 4 to 6 months to prevent early relapse, and maintenance phase treatment continues for 1 or more years for selected patients at increased of recurrence.

Figure 1 Phases of Depression Treatment

Current guidelines provide a range of recommendations for continuation and maintenance phase treatment. For example, the National Institute for Clinical Excellence guidelines (developed by the British National Health Service) recommend ≥ 2 years treatment for patients with 2 or more major depressive episodes accompanied by functional impairment, while the Institute for Clinical Systems Improvement guidelines, a US regional health care collaborative, recommend 6–12 months treatment without specifying which groups should get longer duration of treatment.[9, 10] Since these guidelines were published, new data from randomized trials provide additional evidence on the benefits of antidepressant medication for preventing relapse or recurrence. In addition, systematic reviews provide evidence on potential long-term risks of continuing antidepressant medication.