# EVIDENCE TABLES

Evidence Table 1 Key Question #2 Systematic Review, Hansen, 2008[35]

Studies | Study Characteristics Study Designs | Patient Characteristics | Outcomes Assessed | Relative risks/other summary effect measures | Comments Quality Rating
Doogan & Caillard, 1992[141] Feiger, 1999[142] Gelenberg, 2003[143] Gilaberte, 2001[144] Hochstrasser, 2001[145] Keller, 1998[146] Klysner, 2002[147] Kornstein, 2006[42] Lepine, 2004[43] Lustman, 2006[148] Montgomery, 1993[149] Montgomery, 2004[150] Montgomery & Dunbar, 1993[151] Rapaport, 2004 [not found] Reimherr, 1998[44] Reynolds, 2006[152] Robert & Montgomery, 1995[153] Schmidt, 2000[154] Simon, 2004[155] Terra & Montgomery, 1998[156] Thase, 2001[157] Weihs, 2002[158] Wilson, 2003[159] | No. of studies: 23 placebo controlled RCT Study countries: Most included US Many in UK, France, & Europe Several multinational Study intervention: Second-generation antidepressant: bupropion, citalopram, duloxetine, escitalopram, fluoxetine, fluvoxamine, mirtazapine, nefazadone, paroxetine, sertraline, trazodone, venlafaxine Clinical settings (22/23 articles): Mixed settings: 4 “Outpatient”: 12 Not Given: 6 VA: 0 Civilian: 22 | Total no. of patients: 8241 Age: Mean age range generally 40–50. Two trials w/range 65–87 Gender: Most >60% female Many >65% female Depressive Disorder: 26 required MDD diagnosis, 1 required only QIDS-C-16 > 5. Severity of initial symptoms: Many used HDRS. Some had requirement for # episodes. Race/ethnicity: NG Exclusion: Use of other psychotropics, presence of comorbid psychiatric or medical disease most common | Relapse definition: most used increase in HAMD or MADRS above predefined cutoff pt. Some added clinical criteria. Treatment duration (after acute phase): Continuation: 14–72 weeks Maintenance: 36–100 weeks. 12 trials: f/up <1yr (re-defined as continuation) 11 trials: f/up 1+ yr (re-defined as maintenance) Outcomes: 1) Continuation phase relapse rate compared to placebo 2) Maintenance phase recurrence rate compared to placebo Other Outcomes: 4) Rates of adverse events 5) Rates of loss to f/up attributed to adverse events | [underlined: Relapse] re-defined as relapse w/in 1 yr continuation [underlined: Recurrence] re-defined as relapse w/in 1 yr maintenance Outcomes: 1) Unadjusted frequency of relapse was 22% active treatment, 42% placebo 2) Unadjusted frequency of recurrence was 26% for active treatment, 48% placebo Other Outcomes: 3) Adverse events rates given for individual studies when reported (compared w/acute-phase studies, relative incidence of most common adverse events was lower) 5) Loss to f/up attributed to adverse events was 7% for active treatment and 4% for placebo (did not report significance) | Comments: -In meta-regression, duration of follow-up did not impact effect size -Authors reported fair quality of studies included -Moderate grade evidence Quality Rating: high Focused clinical question? Yes Detailed & exhaustive search? Yes Inclusion/exclusion criteria clearly defined & appropriate? Yes Studies evaluated for quality & appropriately? Yes Assessments of studies reproducible? Yes Measured variability in effect? Yes Differences in how outcomes were reported and analyzed across studies considered? Yes Publication bias assessed? Yes, Clinically important outcomes (harms & benefits) reported? Yes Conclusions supported by data presented? Yes

Evidence Table 2 Key Question #2 Randomized Controlled Trials

Study Characteristics | Research Objective Duration Study Design | Patient Baseline Characteristics | Inclusion/Exclusion Criteria | Outcome Results | Adverse Events (%) | Analysis Quality Rating
Author: Kocsis et al., 2007[37] Country and Setting: United States Outpatient Funding: Wyeth (manufacturer of venlafaxine) | Research Objective: To compare time to recurrence of depression with venlafaxine ER versus placebo Duration of Study: 12-month maintenance phase for venlafaxine ER responders Study Design: Randomized Placebo controlled Overall Total N: 258 (randomized) Intervention: Group 1: Venlafaxine ER 75–300 mg daily Group 2: Placebo | Mean Age: Venlafaxine ER 42.0 Placebo 42.6 Sex (% female): Venlafaxine ER 69% Placebo 67% Race (% white): Venlafaxine ER 81% Placebo 88% Baseline (HDRS) Venlafaxine ER 4.3 Placebo 4.9 | Inclusion Criteria: • ≥ 18 years old • MDD by DSM-IV • Depression symptoms for ≥ 1 month • ≥ 3 prior depressive episodes, 2 in the past 5 years • Two months between episodes • HDRS-17 score ≥ 20 at screening and ≥18 at randomization • Response or remission of intake episode at end of continuation phase Exclusion Criteria: • Failed trial of study medications • Treatment resistant, defined as failure of three med trials, ECT, or psychotherapy • Hypersensitivity to study medications • Alcohol or illicit drug use within 6 months • Seizure disorder • Other serious medical diseases • Other mental illnesses • Pregnant or lactating • ECT within 3 months • Fluoxetine or MAO-I within 30 days • Other antidepressant within 14 days • Any other psychotropic drug 7 days | Venlafaxine ER was associated with significantly lower risk of recurrence in comparison to placebo. Probability of recurrence: Month 6: Venlafaxine ER: 18.8% Placebo: 28.4% Month 12: Venlafaxine ER: 23.1% Placebo: 42% | Headache: Venlafaxine ER 25 Placebo 24 Upper Respiratory Infection: Venlafaxine ER 17 Placebo 12 Dry Mouth: Venlafaxine ER 15 Placebo 11 Insomnia: Venlafaxine ER 14 Placebo 13 Sweating: Venlafaxine ER 14 Placebo 12 Weight Gain: Venlafaxine ER 12 Placebo 7 Dizziness: Venlafaxine ER 11 Placebo 21 Nausea: Venlafaxine ER 11 Placebo 10 Sexual Problems: Venlafaxine ER 11 Placebo 7 | Overall Attrition Rate: Venlafaxine = 50% Placebo = 73% (p<.001) ITT Analysis: Yes Quality Rating: fair? Grps similar at baseline? Yes Outcomes used valid methodology & criteria? Yes, HDRS-17 Subjects & providers blind to intervention status of participants? Yes Outcome assessors blind? Yes Incomplete outcome data adequately addressed? Yes, ITT >10% differential loss to f/up between grps? Yes Overall >30% loss to f/up? Yes, 40% Conflict of interest? Funded by venlafaxine manufacturer Adequate randomization methods? NG Allocation concealment adequate? NG

Evidence Table 3 Key Question #2 Randomized Controlled Trials

Study Characteristics | Research Objective Duration Study Design | Patient Baseline Characteristics | Inclusion/Exclusion Criteria | Outcome Results | Adverse Effects | Analysis Quality Rating
Author: Kornstein et al., 2008[39] Country and Setting: United States Outpatient Funding: Wyeth (manufacturer of venlafaxine) | Research Objective: Evaluate the long-term efficacy of venlafaxine ER =< 225mg/day in patients with recurrent MDD Duration of Study: Two years for venlafaxine ER responders Study Design: Randomized Placebo controlled Overall Total N: 114 Intervention: Group 1: Continue venlafaxine ER 75–225mg/day Group 2: Placebo | Mean Age: Venlafaxine ER 41 Placebo 43.1 Sex (% female): Venlafaxine ER 73 Placebo 63 Race (% white): NG Baseline (HDRS) Venlafaxine 3.2 Placebo 4.5 | Inclusion Criteria: • ≥18 years old • MDD by DSM-IV • Depression symptoms for ≥ 1 month • ≥ 3 prior depressive episodes, 2 in the past 5 years • Two months between episodes • HDRS-17 score ≥20 at screening and ≥18 at randomization • Response or remission of intake episode at end of continuation phase Exclusion Criteria: • Failed trial of study medications • Treatment resistant, defined as failure of three med trials, ECT, or psychotherapy • Hypersensitivity to study medications • Alcohol or illicit drug use within 6 months • Seizure Disorder • Others serious medical diseases • Other mental illnesses • Pregnant or Lactating • ECT within 3 months •Fluoxetine or MAO-I within 30 days • Other antidepressant within 14 days • Any other psychotropic drug 7 days | Kaplan-Meier probability estimate for not experiencing recurrence OR increasing dose to 300mg/day: 67% for venlafaxine ER =< 225 mg 41% for placebo NNT of 4.5 Estimated probability of not having recurrence greater in venlafaxine ER group vs. placebo (76% versus 58%) but did not reach level of statistical significance | Not reported | Overall Attrition Rate: NG ITT Analysis: Not done Quality Rating: fair or poor? Grps similar at baseline? Yes Outcomes used valid methodology & criteria? Partial, HDRS-17 & dose increase of antidepressant Subjects & providers blind to intervention status of participants? Yes Outcome assessors blind? Yes Incomplete outcome data adequately addressed? No, reasons not reported >10% differential loss to f/up between grps? No Overall >30% loss to f/up? No Conflict of interest? Funded by venlafaxine manufacturer Adequate randomization methods? NG Allocation concealment adequate? NG

Evidence Table 4 Key Question #2 Randomized Controlled Trials

Study Characteristics | Research Objective Duration Study Design | Patient Baseline Characteristics | Inclusion/Exclusion Criteria | Outcome Results | Adverse Events (%) | Analysis Quality Rating
Author: Gorwood et al., 2007[38] Country and Setting: 7 European countries Outpatient Funding: H. Lundbeck A/S (manufacturer of escitalopram) | Research Objective: To test the hypothesis that fewer older patients will relapse on escitalopram compared with placebo Duration of Study: 24 week maintenance phase for escitalopram responders after 12 weeks of open label treatment Study Design: Randomized Placebo controlled Overall Total N: 305 (randomized) Intervention: Group 1: escitalopram 10–20 mg/day Group 2: placebo | Mean Age: Escitalopram 73 Placebo 72 Sex (% female): Escitalopram 78% Placebo 79% Race (% white): Escitalopram 99.7% Placebo 100% Baseline (MADRS): Escitalopram 5.1 Placebo 5.1 | Inclusion Criteria: • >= 65 years old • MDD by MINI • Response to a 12 week trial of escitalopram • MADRS score >= 22 • Duration of t index episode of at least 4 weeks • MMSE score >= 24 Exclusion Criteria: • Current or past history of manic or hypomanic episode, psychotic disorder (including MDD with psychotic features), MR, or mental disorders resulting from a general medical condition • Any substance abuse disorder, presence or history of a clinically significant neurologic disorder, neurodegenerative disorder, and any personality disorder. • Significant suicide risk • Recent receipt prior to screening of the following treatments: • antipsychotic drugs, ECT, lithium, carbamazepine, valproate, or valpromide • antidepressants, benzodiazepines, non-benzodiazepine anxiolytics or hypnotics (other than zolpidem, zopiclone, or zaleplon); serotonin agonists (for example, triptans), psychotherapy • hypersensitivity to citalopram and/or escitalopram • resistance to two trials of antidepressants or resistance to citalopram or escitalopram | Escitalopram was four times as effective as placebo in preventing relapse over 24 weeks in older patients with MDD who had achieved full remission Percentage who relapsed: Escitalopram: 9% (13 patients) Placebo: 33% (50 patients) | Any adverse event: Escitalopram 35.3 Placebo 34.9 Diarrhea: Escitalopram 3.3 Placebo 2.6 Dizziness: Escitalopram 4.6 Placebo 3.3 Nausea: Escitalopram 0 Placebo 0 Headache: Escitalopram 2.6 Placebo 3.3 | Overall Attrition Rate: Escitalopram = 15% Placebo = 8.5% (excluding relapsers) ITT Analysis: Yes Quality Rating: Grps similar at baseline? Yes Outcomes used valid methodology & criteria? Yes, MADRS Subjects & providers blind to intervention status of participants? Yes Outcome assessors blind? Yes Incomplete outcome data adequately addressed? Yes, ITT >10% differential loss to f/up between grps? No Overall >30% loss to f/up? No Conflict of interest? Funded by escitalopram manufacturer Adequate randomization methods? Yes Allocation concealment adequate? Yes

Evidence Table 5 Key Question #2 Randomized Controlled Trials

Study Characteristics | Research Objective Duration Study Design | Patient Baseline Characteristics | Inclusion/Exclusion Criteria | Outcome Results | Adverse Events (%) | Analysis Quality Rating
Author: Dobson et al., 2008[36] Country and Setting: United States Outpatient Funding: NIMH | Research Objective: To compare relapse rates among prior behavioral activatio+n, prior cognitive therapy, and antidepressant medication (ADM) to placebo Duration of Study: 2 years of follow up after 16 week acute phase treatment. Pts were all withdrawn from ADM after 1 year. Study Design: Randomized Placebo controlled Overall Total N: 106 (randomized) Intervention: Group 1: paroxetine (28) Group 2: placebo (21) | Baseline characteristics of those randomized to ADM and placebo in the maintenance phase were not separately reported. For all subjects randomized to AMD or placebo: Female 78.2% Caucasian 80.0% Minority 20.0% Married 36.3% Have children 43.6% College education 63.8% | Inclusion Criteria: • response to acute phase treatment for depression with 16 weeks of paroxetine • diagnosis of MDD for index episode on the basis of diagnostic interviews • 20 or above on the Beck Depression Inventory II and scores of 14 or above on the 17-item version of the HDRS Exclusion Criteria: Not explicitly stated in this report | Rates of relapse after 1 year follow up from Cox regression analysis: paroxetine: 53% placebo: 59% (not statistically significantly different) | Not reported | Overall Attrition Rate: ADM = 7% Placebo = 19% ITT Analysis: Unclear Quality Rating: Poor - Fair? Grps similar at baseline? NG Outcomes used valid methodology & criteria? Yes, HRSD Subjects & providers blind to intervention status of participants? Yes Outcome assessors blind? Yes Incomplete outcome data adequately addressed? No, reasons not reported >10% differential loss to f/up between grps? Yes Overall >30% loss to f/up? No Conflict of interest? No, funded by NIMH Adequate randomization methods? Yes Allocation concealment adequate? Yes