# PEER REVIEW

Question: Are the objectives, scope, and methods for this review clearly described?
Reviewer | Comment | Reply
1 | YES. The objectives, scope were very clear and appropriate. The methods were transparent and appropriately rigorous for a best evidence review, even though the types of studies sought to answer KQ1 and KQ2 were very different. It was helpful to have all of the information on search strategies, inclusion/exclusion criteria and data extraction in the appendices. | Acknowledged
2 | The inclusion and exclusion criteria for Key Question 1 greatly diminish the synthesis’s scope. Given this limitation, I know of no additional studies that should have been included in the review for Key Question 1 or 2. | The inclusion/exclusion criteria were developed with the stakeholders to focus on the questions of interest.
2 | In general, the Synthesis needs a strong editing (e.g. ensuring consistency in abbreviations, defining abbreviations before applying them, correcting punctuation and formatting) | Editing has been completed to ensure consistency
2 | In addition, there were several places within the synthesis where this reviewer could not understand the meaning of a sentence. Specifically:; - Page 8, line 11–12 – “For the finding that the MCID is 5” would be best to define this as the Mean Change in Depression Score for MDD; - Page 16, line 11 – “the similarity of groups similar at baseline”; - Page 25, line 2 – “the number needed”…(number of what?); - The Evidence Tables 1–5 are very difficult to read because of in - consistent formatting and text layout. | These sentences have been edited to clarify the meaning. We did not find the Page 25, line 2 reference; on page 26 we state the “number needed to treat to prevent one relapse…”
3 | Yes, all of these aspects are clearly described. | Acknowledged
4 | a) Objectives are clearly defined. | Acknowledged
4 | b) Scope is also clearly defined, with the exception that the assessment tools that are surveyed are those immediately referable to depressive disorders and their symptoms (i.e., disease-specific). One could also perceive quality of life, functional capacities, health services utilization and costs as relevant outcomes. I agree with focusing on disease-specific assessment, and this is clear as the manuscript goes on, but I would make it absolutely clear up front so as to frame the boundaries of this review explicitly. | Edits made to clarify that focus is limited to depression symptom questionnaires
4 | c) Methods are clearly defined. | Acknowledged
Question: Is there any indication of bias in our synthesis of the evidence?
Reviewer | Comment | Reply
1 | NO. Appropriate precautions were used to minimize bias including 1) having 2 researchers review the titles and/or abstracts of articles for potential inclusion, 2) having 1–2 reviewers over-read the data abstraction forms to assure accurate abstraction, 3) using well known criteria to assess the quality of the studies that included items about funding source and conflict of interest (Appendix C) and strength of evidence (GRADE), 4) providing readers with enough detail to assure transparency, and 5) including comments from outsider reviewers in an Appendix. | Acknowledged
2 | It was not clear how this group of authors was selected to conduct the evidence synthesis. Was this a competitive application or were the authors selected based on their willingness to conduct the synthesis, their expertise in the area of study, or other factors? | This has been addressed in the topic refinement section
3 | No, there is no indication of bias | Acknowledged
4 | No | Acknowledged
Question: Are there any studies on responsiveness of depression questionnaires or relapse prevention trials related to this report that we have overlooked?
Reviewer | Comment | Reply
1 | NO. These are difficult studies to do well and get funded appropriately since they require a diagnostic interview as a reference standard (KQ1) and have a long follow-up period (KQ2). I was not surprised that few studies were found. | Acknowledged
2 | None
3 | No, there are no responsiveness studies missed to include in the analysis. However, in the discussion of results, the authors refer to a UK qualitative study suggesting clinicians are skeptical of depression questionnaires. If this study is cited, the authors should also cite two recent studies showing US primary care physicians (Nease et al, 2008) and psychiatrists (Duffy et al) found the PHQ-9 clinically useful and continued to use. | The discussion has been revised and the additional studies referenced
3 | Also, the authors did not include the 10-item CES-D short-form (Andresen et al, 1994). There are probably no studies testing its responsiveness, but I mention it simply because it does fall within the authors’ 10-item inclusion criteria for brief measures.; - Nease DE, Nutting PA, Dickinson WP, Bonham AJ, Graham DG, Gallagher KM, Main DS. Inducing sustainable improvement in depression care in primary care practices. Joint Commission Journal on Quality and Patient Safety 2008;34:247–255.; - Duffy FF, Chung H, Trivedi M, Rae DS, Regier DA, Katzelnick DJ. Systematic use of patient-rated depression severity monitoring: is it helpful and feasible in clinical psychiatry? Psychiatric Services 2008;59:1148–1154.; - Andresen EM, Malmgren JA, Carter WB, Patrick DL. Screening for depression in well older adults: evaluation of a short form of the CESD (Center for Epidemiologic Studies Depression Scale). Am J Prev Med. 1994; 10: 77–84. | The CESD-10 was not excluded but our search did not include terms specific to this instrument. We have updated the search and results. 49 additional citations were identified but none met eligibility criteria
4 | None that meet the defined criteria, to my knowledge | Acknowledged
Question: Please write additional suggestions or additional comments below for this report. If applicable, please indicate the page and line numbers from the draft report.
Reviewer | Comment | Reply
1 | The target audience for this report includes administrators and policy makers. They would benefit from a conclusion section at the end of the Executive Summary that simply stated the conclusions followed by quality of the evidence supporting the conclusion. This could even be 2 bullet points. Administrators and policy makers are likely to start with this bottom line and read backwards if they need more detail. For example, you could use lines 14–16 on page 24, lines 11–15 on page 23, and lines 44–46 and 1–4 on pages 24 and 25 after editing them. For KQ2, it helps to have both the RR and NNT. | We have followed this suggestion
1 | The results section in the Executive Summary was difficult to follow for KQ1, lines 31–43, page 7. The methods paragraph describes the standardized response mean (SRM) then the results start with the mean change score. I would list the mean change score and SRM for 3 months, then for 6 months. Although you save words in the current version, it is harder to read. Also in line 41 define the abbreviation MCID since you use it later. | We have followed this suggestion
1 | Figure 1 on page 13 is difficult to read in its current size. It would be good if it could be enlarged. | The figure has been enlarged
1 | In Table 7 on page 26, it would be helpful to include some data in the comments section after the summary comment, e.g., mean change score expected of responders. Also, I would include the NNT with the RR. | We have followed this suggestion
1 | Appendix B is important to document why studies were excluded/include. Using “not 1,” “not 2,” etc is a bit confusing, but I could not think of a better way to concisely describe these criteria for the table headers. | Modified to improve clarity
1 | In Appendix C, page 37, line 30 has a typo. I think it should read “...evaluated for quality and appropriateness?” | Thank you. Typo corrected
1 | The evidence tables are dense, but the details are important for transparency. | Acknowledged
2 | Key Question 1 In general, this reviewer felt that Key Question 1 was not an “assessment of tools that were responsive to change”, but rather a review of the PHQ-9’s (and at times the PHQ-2’s) responsiveness to change. This apparent bias first appears in the background section in which the synthesis first author’s work (reference 15) concluded that the PHQ-9 had better performance characteristics and gave more information for depression diagnosis than other instruments. Thus, from the very beginning, this reviewer was confused on why Key Question 1 was requested for a synthesis review. Given these issues, the background on Depression Questionnaires either 1) needs to be expanded to describe the 7 other questionnaires that have < 10 items, or 2) for the sake of transparency, the background section should clearly state in the text that the work that identified the PHQ-9 as the optimal self reported primary care depression measure was conducted by the first author of this synthesis. | We have attempted to strengthen the message that we searched for ALL feasible instruments, but only found data for the PHQ. The background has been modified to briefly describe the eligible questionnaires.
2 | The fact that the primary manuscripts reviewed for Key Question 1 (references 29–32) were all conducted by the same first author (Lowe) should be noted in the limitations. | Discussion has been updated to note this issue.
2 | Since the authors note that there has been no work to date measuring responsiveness to change in instruments was for the PHQ-9 and was applied in a population greater than age 60, the Future Research section should also call for additional studies to identify whether or not the PHQ-9 (and other measures) respond to change in younger populations. | No change; the PHQ9 has been evaluated in mid-life and older adults
2 | Key Question 2
2 | Given that the number of prior episodes is a major risk for relapse, did any of the RCT’s reviewed for Key Question 2 address this issue? Though this is alluded to on page 22, lines 17–20, it should be more clearly stated. | The number of prior depressive episodes was not systematically reported in the trials
3 | Page 6, lines 17–36: In paragraph, authors state “Clinical guidelines recommend continuation treatment for 4–6 months … However, clinical guidelines for longer-term maintenance phase treatment are more variable and performance indicators (e.g., HEDIS) do not address maintenance phase treatment.” But Key Question #2 is: “What is the minimum duration of continuation phase treatment to decrease risk of relapse?” Continuation (1st 4–9 months after remission) and maintenance (long-term treatment after continuation) phases of treatment have distinct meanings in some guidelines, and the authors’ going back and forth between these 2 terms (and in other places the vaguer phrase “long-term treatment” leaves the reader confused whether their review is focused on evidence for continuation phase treatment, maintenance phase, or both. Please clarify for reader. | This comment and the following comment have been addressed in the revision. The background on page 6 clarifies that the review addressed continuation and maintenance phase treatment
3 | Page 8, Lines 31–46: This section clarifies the answer to the question above (i.e., this review looks at both continuation and maintenance treatment) – this should be clarified on p. 6 | As above
3 | Page 14, Lines 36–37: There is a short-form of the CES-D (10 items). The reference is provided under #3 above. The authors might note why this was not included in their search. | Previously addressed
3 | Page 15, Lines 7–8: The authors might add to their parenthetical examples of measures longer than 10 items the Inventory for Depressive Symptoms (since it was used in the landmark STAR*D trial where 40% of patients were from primary care) and the CES-D. | This recommendation was followed
3 | Page 18, Lines 7–9: The authors state: “In addition the study team included a biostatistician from Pfizer, and Pfizer funded the current study and the PHQ-9 development, suggesting a potential conflict of interest.” However, unlike drugs sold for profit, the PHQ-9 always has been made available free of charge. Thus, the potential conflict of interest is much weaker than if drug trials were being analyzed. | This is a valid point about the availability free of charge. However, potential COI still exists as increased identification of depression may increase sales or related for-profit products. No change
3 | Page 24, Lines 35–42: The authors state: “Qualitative studies show that patients favor questionnaires to measure depression severity but general practitioners in the UK were cautious about the validity and utility of these measures and skeptical about the motives behind their introduction. General practitioners specifically valued clinical judgment more than objective assessment. Practitioners were aware of the potential for manipulation of indicators for economic reasons. If these findings hold true for VA clinicians, these barriers would need to be addressed for successful implementation of the PHQ-9 (or any other measure) for routine monitoring.” However, two recent studies in the US showed good uptake of the PHQ-9 by primary care physicians (Nease et al 2008) and psychiatry (Duffy et al 2008). | Previously addressed
Question: Recommendations for future ESP topical areas of interest or programmatic comments may also be included at the end of this section.
Reviewer | Comment | Reply
1 | Topics:; 1. Treatment of chronic obstructive pulmonary disease; 2. Palliative chemotherapy for lung, colon, and possibly other cancers | Acknowledged
1 | Programmatic Comments:; 1. Translating evidence syntheses into policy and organizational decisions will be a difficult step. I assume the ESPs are linked to OQP, but there should be outreach to VISNs and medical centers. | Acknowledged
2 | None
3 | None at this time
4 | If feasible, a review of evidence-based methods and data on suicide risk evaluation in primary care settings would be helpful | Acknowledged