# QUALITY RATINGS

## QUALITY RATING FOR KEY QUESTION #1, ASSESSMENT TOOLS RESPONSIVE TO CHANGE

Was the criterion standard applied and interpreted blinded to the results of the depression questionnaire?

Was the depression questionnaire applied and interpreted blinded to the results of the criterion standard?

Was the interview-based criterion standard a validated measure of depression severity?

Did follow-up of the enrolled sample exceed 80%?

Was the analysis appropriate to the study question?

Was the study funded by the pharmaceutical industry?

Was a conflict of interest disclosure given? If given, was there a potential conflict of interest?

## QUALITY RATING FOR KEY QUESTION #2, SYSTEMATIC REVIEWS

Was a focused clinical question clearly stated?

Was the search for relevant studies detailed and exhaustive?

Were inclusion/exclusion criteria clearly defined and appropriate?

Were primary studies evaluated for quality and appropriateness?

Were assessments of studies reproducible?

Were analyses conducted to measure variability in effect?

Were differences in how outcomes were reported and analyzed across studies were taken into consideration?

Was publication bias assessed?

Were clinically important outcomes (harms and benefits) reported?

Were the conclusions supported by the data presented?

## QUALITY RATING FOR KEY QUESTION #2, RANDOMIZED CONTROLLED TRIALS

Were the groups similar at baseline in terms of baseline characteristics and prognostic factors?

Were depression outcomes assessed using a valid methodology and criteria?

Were subjects and providers blind to the intervention/exposure status of participants?

Were outcome assessors blind to exposure/intervention status?

Were incomplete outcome data adequately addressed?

Was there an important differential loss to follow-up between the compared groups (defined as ≥ 10%)?

Was there an overall high loss to follow-up (≥ 20% for studies <12 months and ≥ 30% for studies of 12 month or longer duration)

Was there a conflict of interest?

Were the methods used for randomization adequate?

Was allocation concealment adequate?