# FULL TEXT EXCLUSIONS

## Inclusion Criteria for Key Question #1, Assessment Tools Responsive to Change

1. One of the specified instruments (PHQ-9, Beck Fast Screen, CESD-10, GDS-15, SDDS-PC, DEPS, PRIME MD)
2. Adults with depressive disorder: outpatient setting
3. Comparator: Comparison to an interview-based instrument
4. Study Design: Longitudinal
5. Study Design: Sample > 50
6. English language article

| General Exclusion Criteria*
Author & Ref # | NOT 1. | NOT 2. | NOT 3. | NOT 4. | NOT 5. | NOT 6.
Ahava, 1998[51] | X
Adler, 2004[52] | | | X
Allard, 2004[53] | X
Altamura, 1989[54] | X
Amsterdam, 2008[55] | | X
Babyak, 2000[56] | X
Baldwin, 2008[57] | X
Barbosa, 2003[58] | X
Berkman, 2003[59] | X
Berlim, 2005[60] | | | | | | X
Berlim, 2007[61] | | | | | | X
Boyer, 1998[62] | X
Brody, 2006[63] | | | X
Brown, 2000[64] | X
Brown, 2005[65] | X
Cassidy, 2005[66] | | | | | X
Casten, 2000[67] | | X
Chen, 2006[68] | | | | | | X
Conradi, 2007[69] | X
Cook,1999[70] | | | | | X
Corney, 2005[71] | | | X
Coulehan, 1997[72] | X
Dalton, 2000[73] | | | | | X
Davies, 2003[74] | | | | | X
DeBattista, 2003[75] | | | | | X
Dori, 1999[76] | X
Dubovsky, 2001[77] | | | | | X
Dunner, 1987[78] | X
Einarson, 2004[79] | X
Fava, 1999[80] | | | | | X
Fawcett, 1987[81] | X
George, 1999[82] | X
George, 2008[83] | X
Goodnick, 1997[84] | | | | | X
Goodnick, 1998[85] | X
Judd, 2004[86] | X
Kates, 2002[87] | X
Koivumaa-Honkanen, 2008[88] | X
Koran, 1995[89] | X
Kroenke, 2006[90] | X
Lesperance, 2007[91] | X
Lett, 2007[92] | X
Levitt, 1999[93] | | | | | X
Liebowitz, 2007[94] | X
Lustman, 1998[95] | | | X
Lustman, 2000[96] | X
Lydiard, 1997[97] | X
Mazeh, 2007[98] | | | | | X
McIntyre, 2005[99] | X
Mohamed, 2006[100] | X
Mulrow, 1998[101] | X
Mynors-Wallis, 2000[102] | X
Patkar, 2006[103] | X
Perez, 1999[104] | X
Picardi, 2005[105] | | X
Pollock, 1989[106] | | X
Posternak, 2001[107] | X
Proudfoot, 2003[108] | | | X
Pyne, 2002[109] | | X
Quilty, 2008[110] | X
Raskin, 2003[111] | X
Raskin, 2007[112] | X
Rollman, 2002[113] | X
Rush, 2005[114] | X
Rutherford, 2007[115] | | | | | | X
Salkovskis, 2006[116] | X
Shelton, 2001[117] | X
Singh, 2001[118] | | | | | | X
Skevington, 2001[119] | X
Spalletta, 2002[120] | | | | | | X
Stark, 1985[121] | | | X
Szegedi, 2005[122] | X
Thase, 1997[123] | X
Trivedi, 2004[124] | X
Tutty, 2000[125] | X
van Gurp, 2002[126] | X
van Marwijk, 2008[127] | | | X
Vinkers, 2004[128] | | X
Wade, 2008[129] | X
Wise, 2007[130] | X

Items in the table (e.g. Not 1) correspond to the inclusion criteria listed above the table

## Inclusion Criteria for Key Question #2, Systematic Reviews

1. Systematic review evaluating anti-depressant vs. placebo. A systematic review contains a methods section with search strategy and approach to synthesizing the data
2. Patients: Adults with major depressive disorder who have remitted or improved substantially with anti-depressant medication, English language article
3. Outcome: Relapse/recurrence

| General Exclusion Criteria*
Author & Ref # | NOT 1. | NOT 2. | NOT 3.
Bauer 2009[131] | | | X
Gartlehener 2008[132] | | | X
Quaseem 2008[133] | X
Anderson 2008[134] | X
Papakostas 2007[135] | | | X
Furukawa 2007[136] | X
Zimmerman 2007[137] | | | X
Lam 2004[138] | X

Items in the table (e.g. Not 1) correspond to the inclusion criteria listed above the table*

## Inclusion Criteria for Key Question #2, Randomized Controlled Trials

1. Study Design: Randomized Controlled Trial
2. Patients: Adults
3. Outcome: Relapse/recurrence
4. Compares anti-depressant vs. placebo
5. Patients: Adults with major depressive disorder who have remitted or improved substantially with anti-depressant medication
6. English language article

| General Exclusion Criteria^*^
Author & Ref # | NOT 1. | NOT 2. | NOT 3. | NOT 4. | NOT 5. | NOT 6.
Dombrovski 2008[139] | | | | | X
Keller 2007[140] | | | | X

* Items in the table (e.g. Not 1) correspond to the inclusion criteria listed above the table