# SEARCH STRATEGIES

## KEY QUESTION #1

Database: PubMed ^®^ <1950 to February 2, 2009>

1 | “Depressive Disorder, Major”[Mesh] OR (major AND depression) | 32348
2 | PHQ9 OR “Patient Health Questionnaire” OR “Beck Depression Inventory” OR BDI OR BDI-II OR GDS OR “Geriatric Depression Scale” OR SDDS-PC OR “symptom driven diagnostic system primary care” OR PRIMEMD OR “Primary care evaluation of mental disorders” OR DEPS OR “CESD” OR “CES-D” OR (“Center” AND Epidemiologic* AND Stud* AND Depression) OR “CESD-10” | 11913
3 | (change OR changes OR Improv* OR decreas*) AND (score OR scale* OR scores OR responsiv* OR sensitiv*) | 447184
4 | #1 AND #2 AND #3 | 522
5 | (questionnaire OR psychometrics) AND (“Depressive Disorder, Major”[Mesh] OR (major AND depression)) AND (((responsiv*[tw] OR sensitiv*[tw]) AND (change[tw] OR changes[tw])) OR (clinical*[tw] AND important[tw] AND (change[tw] OR changes[tw]))) | 126
6 | #4 OR #5 | 626
7 | #6 Limits: Humans, English, All Adult: 19+ years | 516

Database: PsychInfo <up to February 2, 2009>

1 | major depression/ | 58084
2 | major depression.tw. | 16118
3 | (PHQ9 or “Patient Health Questionnaire” or “Beck Depression Inventory” or BDI or BDI-II or GDS or “Geriatric Depression Scale” OR SDDS-PC or “symptom driven diagnostic system primary care” or PRIMEMD or “Primary care evaluation of mental disorders” or DEPS).tw. | 9324
4 | ((change or changes or Improv* or decreas*) and (score or scale* or scores or responsiv* or sensitiv*)).tw. | 82044
5 | #1 or #2 | 61641
6 | #3 and #4 and #5 | 893
7 | limit 6 to ((“followup study” or “longitudinal study” or “prospective study” or “systematic review”) AND “adulthood age 18 yrs AND older” AND “peer-reviewed journal” AND English AND human) | 157

## KEY QUESTION #2, SYSTEMATIC REVIEWS

Database: PubMed ^®^ <1950 to March 02, 2009>

1 | (“Depressive Disorder”[Mesh] OR “major depression”) | 63463
2 | (antidepress* OR “Antidepressive Agents”[Mesh] OR “Antidepressive Agents “[Pharmacological Action]) | 114617
3 | (recurrence[Mesh] OR relaps* OR recurren*) | 410446
4 | #1 AND #2 AND #3 | 2073
5 | #4 AND systematic[sb] | 106

## KEY QUESTION #2, RANDOMIZED CONTROLLED TRIALS

Database: PubMed ^®^ <1950 to March 01, 2009>

1 | (“Depressive Disorder”[Mesh] OR “major depression”) | 63463
2 | (antidepress* OR “Antidepressive Agents”[Mesh] OR “Antidepressive Agents “[Pharmacological Action]) | 114617
3 | (recurrence[Mesh] OR relaps* OR recurren*) | 410446
4 | (randomized controlled trial[Publication Type] OR (randomized[Title/Abstract] AND controlled[Title/Abstract] AND trial[Title/Abstract]) | 275051
5 | #1 AND #2 AND #3 AND #4 | 428
6 | Limits: Publication Date from 2007/01/01 to 2009/03/1, Humans, English, All Adult: 19+ years | 48