# REFERENCES

Higgins JPT, Green S, editors. Cochrane handbook for systematic reviews of interventions 4.2.5 [updated May 2005]. The Cochrane Library, John Wiley and Sons. Chichester, UK. 2005:187-8.
Adler DA, Bungay KM, et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. Gen Hosp Psychiatry. 2004;26(3):199-209. [pmid: 15121348].
Agency for Health Care Policy and Research. 1993. Clinical Practice Guideline: Quick Reference Guide for Clinicians, AHCPR Publication No. 93–0552.
Araya R, Rojas G, et al. Treating depression in primary care in low-income women in Santiago, Chile: a randomised controlled trial. Lancet. 2003;361(9362):995-1000. [pmid: 12660056].
Bartels SJ, Coakley EH, et al. Improving access to geriatric mental health services: a randomized trial comparing treatment engagement with integrated versus enhanced referral care for depression, anxiety, and at-risk alcohol use. Am J Psychiatry. 2004;161(8):1455-62. [pmid: 15285973].
Berkey CS, Hoaglin DC, et al. A random-effects regression model for meta-analysis. Stat Med. 1995;14(4):395-411. [pmid: 7746979].
Bodenheimer T, Wagner EH, et al. Improving primary care for patients with chronic illness. JAMA. 2002;288(14):1775-9. [pmid: 12365965].
Bodenheimer T, Wagner EH, et al. Improving primary care for patients with chronic illness: the chronic care model, Part 2. JAMA. 2002;288(15):1909-14. [pmid: 12377092].
Bower P, Sibbald B. On-site mental health workers in primary care: effects on professional practice. Cochrane Database Syst Rev. 2000;(3):CD000532.
Brook OH, van out H, et al. A pharmacy-based coaching program to improve adherence to antidepressant treatment among primary care patients. Psychiatr Serv. 2005;56(4):487-9. [pmid: 15812103].
Bruce ML, Ten Have TR, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004;291(9):1081-91. [pmid: 14996777].
Butler M, Kane RL, et al. 2008. Integration of Mental Health/Substance Abuse and Primary Care. AHRQ Publication No. 09-E003. Oct. Available at http://www.ahrq.gov/clinic/tp/mhsapctp.htm. Accessed 1/09.
Capoccia KL, Boudreau DM, et al. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. Am J Health Syst Pharm. 2004;61(4):364-72. [pmid: 15011764].
Craven MA, Bland R. Shared mental health care: a bibliography and overview. Can J Psychiatry. 2002;47(2 Suppl 1):iS-viiiS. 1S. 103S. [pmid: 11989111].
Craven MA, Bland R. Better practices in collaborative mental health care: an analysis of the evidence base. Can J Psychiatry. 2006;51(6 Suppl 1):7S-72S. [pmid: 16786824].
Datto CJ, Thompson R, et al. The pilot study of a telephone disease management program for depression. Gen Hosp Psychiatry. 2003;25(3):169-77. [pmid: 12748029].
Dietrich AJ, Oxman TE, et al. Re-engineering systems for the treatment of depression in primary care: cluster randomised controlled trial. BMJ. 2004;329(7466):602. [pmid: 15345600].
Dobscha SK, orson KC, et al. Depression decision support in primary care: a cluster randomized trial. Ann Intern Med. 2006;145(7):477-87. [pmid: 17015865].
Finley PR, Rens HR, et al. Impact of a collaborative care model on depression in a primary care setting: a randomized controlled trial. Pharmacotherapy. 2003;23(9):1175-85. [pmid: 14524649].
Fortney JC, et al. 2006. Telemedicine-based collaborative care to reduce rural disparities. Health Services Research and Development Meeting. Washignton, DC.
Gilbody S, Bower P, et al. Collaborative care for depression: a cumulative meta-analysis and review of longer-term outcomes. Arch Intern Med. 2006;166(21):2314-21. [pmid: 17130383].
Gilbody S, Bower P, et al. Costs and consequences of enhanced primary care for depression: systematic review of randomised economic evaluations. Br J Psychiatry. 2006;189:297-308. [pmid: 17012652].
Gilbody S, Whitty P, et al. Educational and organizational interventions to improve the management of depression in primary care: a systematic review. JAMA. 2003;289(23):3145-51. [pmid: 12813120].
Goldberg DP, Steele JJ, et al. Training family doctors to recognize psychiatric illness with increased accuracy. Lancer. 1980:521-523.
Hedrick SC, Chaney EF, et al. Effectiveness of collaborative care depression treatment in Veterans’ Affairs primary care. J Gen Intern Med. 2003;18(1):9-16. [pmid: 12534758].
Hepner KA, Rowe M, et al. The effect of adherence to practice guidelines on depression outcomes. Ann Intern Med. 2007;147(5):320-9. [pmid: 17785487].
Higgins J, Green S. Approaches to summarizing the validity of studies. Cochrane Handbook for Systematic Reviews of Interventions 4.2.5 [updated May 2005]; Section 6.7. The Cochrane Library. 2005;3. Chichester, UK. John Wiley & Sons.
Hunkeler EM, Meresman JF, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care. Arch Fam Med. 2000;9(8):700-8. [pmid: 10927707].
IMPACT Implementation Center. 2008. Tools and Materials for Depression Care. Available at: http://www.rand.org/health/surveys_tools/pic.htm. Accessed 1/09.
Institute of Medicine. 2001. Crossing the Quality Chasm : A New Health System for the 21st Century. Washington. National Academy Press.
Katon W. Collaborative care: patient satisfaction, outcomes, and medical cost-offset. Fam Syst Med. 1995;13(3–4):351-65.
Katon W, Robinson P, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. 1996;53(10):924-32. [pmid: 8857869].
Katon W, Rutter C, et al. A randomized trial of relapse prevention of depression in primary care. Arch Gen Psychiatry. 2001;58(3):241-7. [pmid: 11231831].
Katon W, Schulberg H. Epidemiology of depression in primary care. Gen Hosp Psychiatry. 1992;14(4):237-47. [pmid: 1505745].
Katon W, von Korff M, et al. Adequacy and duration of antidepressant treatment in primary care. Med Care. 1992;30(1):67-76. [pmid: 1729588].
Katon W, Von Korff M, et al. Rethinking practitioner roles in chronic illness: the specialist, primary care physician, and the practice nurse. Gen Hosp Psychiatry. 2001;23(3):138-44. [pmid: 11427246].
Katon W, Von Korff M, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: a randomized trial. Arch Gen Psychiatry. 1999;56(12):1109-15. [pmid: 10591288].
Katon W, Von Korff M, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. 1995;273(13):1026-31. [pmid: 7897786].
Katon WJ, Von Korff M, et al. Collaborative management to achieve treatment guidelines: Impact on depression in primary care. Journal of American Medical Association. 1995;273(13):1026-1031.
Katon WJ, Von Korff M, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. 2004;61(10):1042-9. [pmid: 15466678].
Katzelnick DJ, Simon GE, et al. Randomized trial of a depression management program in high utilizers of medical care. Arch Fam Med. 2000;9(4):345-51. [pmid: 10776363].
Lin EH, Katon WJ, et al. Low-intensity treatment of depression in primary care: is it problematic?. Gen Hosp Psychiatry. 2000;22(2):78-83. [pmid: 10822095].
Lo Sasso AT, Rost K, et al. Modeling the impact of enhanced depression treatment on workplace functioning and costs: a cost-benefit approach. Med Care. 2006;44(4):352-8. [pmid: 16565636].
Macarthur Foundation. 2003. Depression in Primary Care Tools and Materials. Chicago, IL. John D. and Catherine T. MacAuthur Foundation. Available at: http://depression-primary-care.org/. Accessed 1/09.
Mann AH, Blizard R, et al. An evaluation of practice nurses working with general practitioners to treat people with depression. Br J Gen Pract. 1998;48(426):875-9. [pmid: 9604408].
Miles MB, Huberman AM. 1994. Qualitative Data Analysis: A source book for new methods. Thousand Oaks. Sage Publications.
Mitchell G, Del Mar C, et al. Does primary medical practitioner involvement with a specialist team improve patient outcomes? A systematic review. Br J Gen Pract. 2002;52(484):934-9. [pmid: 12434964].
Murray CJ, Lopez AD. Alternative projections of mortality and disability by cause 1990–2020: Global Burden of Disease Study. Lancet. 1997;349(9064):1498-504. [pmid: 9167458].
Ormel JVM, Ustun TB, Pini S, Korten A, Oldehinkel T. Common mental disorders and disability across cultures. Results from the WHO Collaborative Study on Psychological Problems in General Health Care. JAMA. 1994;272:1741-8. [pmid: 7966922].
Oslin DW, Sayers S, et al. Disease management for depression and at-risk drinking via telephone in an older population of veterans. Psychosom Med. 2003;65(6):931-7. [pmid: 14645769].
Oxman TE, Dietrich AJ, et al. A three-component model for reengineering systems for the treatment of depression in primary care. Psychosomatics. 2002;43(6):441-50. [pmid: 12444226].
Peveler R, George C, et al. Effect of antidepressant drug counselling and information leaflets on adherence to drug treatment in primary care: randomised controlled trial. BMJ. 1999;319(7210):612-5. [pmid: 10473477].
RAND. 2000. Partners in Care Tools and Materials. Available at: http://www.rand.org/health/surveys_tools/pic.htm. Accessed 1/09.
Rickles NM, Svarstad BL, et al. Pharmacist telemonitoring of antidepressant use: effects on pharmacist-patient collaboration. J Am Pharm Assoc (2003). 2005;45(3):344-53. [pmid: 15991756].
Robinson KA, Dickersin K. Development of a highly sensitive search strategy for the retrieval of reports of controlled trials using PubMed. Int J Epidemiol. 2002;31(1):150-3. [pmid: 11914311].
Rollman BL, Hanusa BH, et al. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
Rost K, Nutting P, et al. Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. J Gen Intern Med. 2001;16(3):143-9. [pmid: 11318908].
Rubenstein LV, Calkins DR, et al. Improving patient function: A randomized trial of functional disability screening. Annals of Internal Medicine. 1989;111:836-842. [pmid: 2683917].
Rubenstein LV, McCoy JM, et al. Improving patient quality of life with feedback to physicians about functional status. J Gen Intern Med. 1995;10(11):607-14. [pmid: 8583263].
Rubenstein, L. V., L. S. Meredith, et al.2006 Impacts of evidence-based quality improvement on depression in primary care: a randomized experiment J Gen Intern Med 21 10 1027 35 Epub 2006 Jul 7 16836631
Rubenstein LV, Parker LE, et al. Understanding team-based quality improvement for depression in primary care. Health Serv Res. 2002;37(4):1009-29. [pmid: 12236381].
Schoenbaum M, Sherbourne C, et al. Gender patterns in cost effectiveness of quality improvement for depression: results of a randomized, controlled trial. J Affect Disord. 2005;87(2–3):319-25. [pmid: 16005520].
Schoenbaum M, Unutzer J, et al. The effects of primary care depression treatment on patients’ clinical status and employment. Health Serv Res. 2002;37(5):1145-58. [pmid: 12479490].
Simon GE, Ludman EJ, et al. Telephone psychotherapy and telephone care management for primary care patients starting antidepressant treatment: a randomized controlled trial. JAMA. 2004;292(8):935-42. [pmid: 15328325].
Simon GE, VonKorff M. Recognition, management, and outcomes of depression in primary care. Arch Fam Med. 1995;4(2):99-105. [pmid: 7842160].
Simon GE, VonKorff M, et al. Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care. BMJ. 2000;320(7234):550-4. [pmid: 10688563].
Stata. 2006. Statistical Software Manual. College Station, TX. Stata Corp.
Stone EG, Morton SC, et al. Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Ann Intern Med. 2002;136(9):641-51. [pmid: 11992299].
Sutton AJ, AK, Jones DR, Sheldon TR, Song F. Methods for Meta-Analysis in Medical Research. Wiley. 2000:29-31.
Swindle RW, Rao JK, et al. Integrating clinical nurse specialists into the treatment of primary care patients with depression. Int J Psychiatry Med. 2003;33(1):17-37. [pmid: 12906341].
Thompson C, Kinmonth AL, et al. Effects of a clinical-practice guideline and practice-based education on detection and outcome of depression in primary care: Hampshire Depression Project randomised controlled trial. Lancet. 2000;355(9199):185-91. [pmid: 10675118].
Unutzer J, Katon W, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. 2002;288(22):2836-45. [pmid: 12472325].
Von Korff M, Gruman J, et al. Collaborative management of chronic illness. Annals of Internal Medicine. 1997;127(12):1097-102. [pmid: 9412313].
Wagner EH, Austin BT, et al. Improving chronic illness care: translating evidence into action. Health Aff (Millwood). 2001;20(6):64-78. [pmid: 11816692].
Wagner EH, Austin BT, et al. Improving chronic illness care: translating evidence into action. Health Aff (Millwood). 2001;20(6):64-78. [pmid: 11816692].
Wagner EH, Glasgow RE, et al. Quality Improvement In Chronic Illness Care: A Collaborative Approach. Joint Commission Journal on Quality Improvement. 2001;27(2):63-80. [pmid: 11221012].
Waterreus A, Blanchard M, et al. Community psychiatric nurses for the elderly: well tolerated, few side-effects and effective in the treatment of depression. J Clin Nurs. 1994;3(5):299-306. [pmid: 7834140].
Wells KB, Sherbourne C, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. 2000;283(2):212-20. [pmid: 10634337].
Wells K, Sherbourne C, et al. Quality improvement for depression in primary care: do patients with subthreshold depression benefit in the long run?. Am J Psychiatry. 2005;162(6):1149-57. [pmid: 15930064].
Williams JW Jr, MGerrity, et al. Systematic review of multifaceted interventions to improve depression care. Gen Hosp Psychiatry. 2007;29(2):91-116. [pmid: 17336659].
Zhang M, Rost KM, et al. A community study of depression treatment and employment earnings. Psychiatr Serv. 1999;50(9):1209-13. [pmid: 10478909].