# EVIDENCE REPORT

## INTRODUCTION

Practice improvement to assure appropriate depression care is urgently needed. According to projections from the World Health Organization, depression will be the second leading cause of disability in the developed world by 2020 (Ormel J 1994; Murray and Lopez 1997). Primary care clinicians (PCCs) care for approximately two thirds of depressed individuals. Rates of optimal quality of care for depression, however, are low (Simon and VonKorff 1995; Hepner, Rowe et al. 2007).

Collaborative care models show promise as guides for achieving appropriate depression care in ordinary primary care practices. These models are organizational interventions that target the structure of primary care practice through changes in elements such as those identified in the Chronic Illness Care Model (Wagner, Austin et al. 2001). A previous rigorously conducted meta-analysis of thirty-seven randomized trials (Gilbody, Bower et al. 2006; Gilbody, Bower et al. 2006) showed the effectiveness of multifaceted interventions based on the collaborative care model (Katon 1995) for improving depression care and outcomes for primary care patients. These studies followed several other literature syntheses on improving care for depression in primary care that drew similar conclusions on the effectiveness of multi-component models (Gilbody, Whitty et al. 2003; Craven and Bland 2006). The success of multi-faceted collaborative care interventions contrasted with prior and subsequent targeted guideline implementation strategies such as screening alone(Goldberg, Steele et al. 1980; Rubenstein, Calkins et al. 1989), screening plus reminders or management suggestions (Rubenstein, McCoy et al. 1995; Rollman, Hanusa et al. 2002) or education alone(Thompson, Kinmonth et al. 2000).

Not only did collaborative care prove to be effective, it also proved to be cost-effective. A meta-analysis of 11 cost-effectiveness studies on collaborative care showed that the multi-component collaborative care models are within usually accepted ranges of cost-effectiveness, while educational interventions alone are not cost-effective (Gilbody, Bower et al. 2006).

It is important in considering the impact of collaborative care interventions in primary care to recognize that depression of lesser symptom severity or complexity has severe impacts over time if not corrected (Hays, 1995). The effects of depression on job loss (Zhang, Rost et al. 1999; Schoenbaum, Unutzer et al. 2002; Schoenbaum, Sherbourne et al. 2005; Lo Sasso, Rost et al. 2006), social and family relationships, financial decision-making, and other aspects of functioning mean that early in its course, depression can initiate a potentially preventable downward spiral. Thus, effective treatment of the less dramatic presentations of major depression is critical to disability prevention. Yet low complexity patients are less likely to receive appropriate attention under usual care circumstances. Patients with severe depression symptoms and/or psychiatric comorbidities are more likely to be recognized in primary care settings than those with fewer symptoms (Borowsky 2000; Pfaff 2005; Barkow 2004). These complex patients are more likely to be referred to mental health specialists and to comply with the referral as part of usual care (Bartels 2004; Borowsky 2000).

The wealth of evidence on the effectiveness and cost-effectiveness of collaborative care, however, is not matched by a clear understanding of what collaborative care features practices must implement to achieve results similar to the studies. Collaborative care intervention descriptions vary both in terms of what was done and in how intervention features are described. Two meta-analyses of specific intervention features relevant to collaborative care had negative results i.e., the identified feature was not associated with greater effect sizes address collaborative care, but focused on organizational interventions for depression care improvement in primary care. The first was a Cochrane review of the effect of collocation of mental health specialists in primary care (Bower and Sibbald 2000; Mitchell, Del Mar et al. 2002). The second was a study of integration of mental health or substance abuse treatment in primary care (Butler 2008). Thus, to date, there have been no quantitative analyses of features of collaborative care that have been able to clearly identify intervention features associated with effectiveness.

The purpose of this study is to support enhanced implementation of effective collaborative care for depression by identifying key intervention features that are consistently associated with greater impacts on outcomes across the many studies of this model. This will enable the development of practice guidelines, or best practices, that incorporate the best current evidence on the specific organizational features necessary for providing effective care to depressed primary care patients. It will also foster the development of measures of model adherence for use in determining the extent to which collaborative care as implemented matches the key features identified from the literature.

## BACKGROUND

Conceptual Approach: Our basic conceptual approach to depression collaborative care was shaped by the chronic illness care model (Fig 1) first described by Wagner et al (Wagner, Austin et al. 2001). We viewed the collaborative care model for depression as a specific case of the chronic illness care model, and identified variables describing study interventions accordingly.

Fig. 1 Chronic Illness Care Model

The Chronic Illness Care model postulates types of organizational changes that can support guideline-concordant clinical care. In the case of depression, several specific aspects of depression care highlighted in clinical practice guidelines (Agency for Health Care Policy and Research 1993) are targeted by studies using a Chronic Illness Care type collaborative care approach. These include depression detection (i.e., screening or case finding), assessment (i.e., diagnosis of depression, comorbidities, and contributing factors), proactive follow-up (i.e., contacting patients to support self-management), and mental health specialty input or care for complex patients.

Collaborative Care for Depression: The early studies showing that improved depression outcomes can be achieved by multi-component organizational interventions that support primary care for depression were developed empirically, rather than theoretically. Intervention developers refered to these interventions as depression collaborative care based on their emphasis on linking clinicians and patients in a joint management effort(Katon, Von Korff et al. 1995; Von Korff, Gruman et al. 1997) (Fig. 2). Later developers also emphasized collaboration in terms of the enhancement of links between mental health, primary care, and patients through care management. However, as implemented across a variety of similarly constructed interventions, the term collaborative care has come to incorporate additional features and functions.

Fig. 2 Depression Collaborative Care

In general, collaborative care models aim to support primary care to prevent commonly identified deficits in how depression care is provided using organizational changes, tools, and materials (MacArthur 2003, RAND 2000, IMPACT Implementation Center 2008, Hepner, Rowe et al. 2007). Care deficits addressed by collaborative care occur in fulfilling the set of functions necessary for achieving appropriate depression treatment. These functions are: 1) detecting depressed patients; 2) assessing patients with depression symptoms for depression diagnosis, symptom severity, history, and comorbidities; 3) triaging sicker patients to be seen by or followed by mental health specialists; 4) initiating treatment that accounts for patient preferences and characteristics; 5) promoting treatment adherence through early, active follow-up; 6) adjusting treatment based on patient depression symptom response; and 7) re-assessing patient symptoms after treatment to determine need for treatment continuation. All of these activities can be thought of as promoting 8) patient self-management support. These functions are difficult to deliver as part of routine primary care. Common barriers are that most patients do not wish to and/or are not able to access mental health specialists; resources for intensive individual mental health specialist care for mildly depressed patients are not available; patient and provider resources for attending primary care as frequently as needed during early treatment are not available; and time and training for primary care clinicians to perform needed symptom and history assessments are not available. Collaborative care models identify organizational resources, as indicated in the chronic illness care model, to overcome these barriers.

Consistent with the chronic illness care model, a major emphasis of collaborative care interventions is delivery system design. Typically, these models identify personnel, such as nurses or pharmacists, to fill gaps in usual care for the depression care functions that are most difficult for primary care clinicians to fulfill. These personnel follow designated procedures, usually with identified decision support, including provider education. In some cases, clinical information systems are engaged to facilitate key functions. Patient self-management support is considered important for all patients with chronic illnesses. Depressed patients, however, by virtue of their depressive illness, feel hopeless, helpless, and apathetic characteristics that promote the low treatment adherence seen in many studies (Katon, von Korff et al. 1992; Lin, Katon et al. 2000). Collaborative care interventions provide patient self management support by promoting pro-active follow-up (i.e., follow-up that is initiated by the provider, rather than the patient); by educating patients; and/or by activating patients through behaviorally-oriented interventions such as problem-solving therapy or cognitive behavioral therapy.

Multifaceted organizational interventions carried out in routine care settings are challenging to synthesize through literature review. These interventions include features adapted to individual organizational settings and resources, preventing uniformity of types of interventions across settings. Echoing findings on collaborative care for depression, we found that multi-faceted organizational interventions targeting Chronic Illness Care Model primary care organizational features such as staffing and delivery system design were more likely to be effective in improving prevention quality than were other types of interventions (Stone, Morton et al. 2002). However, also similarly to prior reviews, we were unable to achieve a high level of specificity about the characteristics of these organizational interventions. Thus, while a strong signal can be detected across broad types of multifaceted interventions, it has been challenging to translate the broad signal into specific guidance for spreading these interventions.

The first set of literature syntheses looked for a signal identifying a general type of depression care improvement intervention with positive effects. These studies identified multi-faceted collaborative care or chronic illness care type interventions as the only general type of intervention to date that had robustly impacted depression outcomes for populations of patients identified as depressed in primary care (Craven and Bland 2002; Gilbody, Whitty et al. 2003). Following this signal, the 2006 Gilbody meta-analysis selected studies based on designation of one or more staff members to support management of depressed patients (care management), and showed overall effectiveness of the 37 selected randomized trials (Gilbody, Bower et al. 2006). A cost effectiveness meta-analysis of a similar set of interventions studies (Gilbody, Bower et al. 2006) showed that these models are relatively inexpensive, may save costs in the long run, and are more cost-effective in terms of benefits to patients than many other commonly-used clinical interventions. All of these literature analyses found that studies varied substantially in the exact configurations of intervention components and features used, as well as in what and how they report on intervention features and outcomes.

In addition to variations in intervention design, studies vary in terms of the patient populations they enroll and in other aspects of their evaluations. For example, some studies include patients screened in as depressed from a primary care population, and referred to collaborative care. Other studies identify patients by asking primary care clinicians or by searching pharmacy data bases for patients recently started on antidepressants. The range of depression symptoms required for inclusion varies from subsyndromal to very severe. Some studies exclude patients with psychiatric comorbidities, while others include them. Most studies exclude the most complex patients. Some studies involve multiple practices, while others focus on only one or two. Some studies involve large practices, often within managed care organizations, while others address small network or private practices. Few studies report in detail on the dynamics of mental health specialty referral or communication (Butler 2008). Overall, little is known about how the variety of possible features affect the chances of impacting patient outcomes.

In this study, we aimed to build on previous reviews using both quantitative and qualitative techniques, combined with extensive queries to authors to obtain unpublished intervention details. We aimed to identify articles that represented organizational change approaches to improving depression care for patients in primary care as emphasized in the chronic illness care model. Based on these, we aimed to describe the set of features that characterize high impact collaborative care interventions as a group. We also aimed to identify a short list of features that, when present, are associated with greater intervention impact. We additionally identified a set of “optional” features that varied across studies but were not associated with differential outcome effects. A short list of such features can assist those implementing collaborative care as a depression quality improvement strategy to choose intervention designs (or change strategies, in quality improvement terminology) with the greatest probability of reproducing the effects of high impact depression care interventions from the literature. Finally, we aimed to add to our current understanding of how to use literature analysis to understand multi-component interventions by using innovative qualitative approaches to overcome some of the methodological limitations of meta-regression for understanding how to implement successful depression collaborative care interventions.

The rationale behind supporting these aspects of depression care delivery is strong, in that depression quality of care is known to be suboptimal in each of these areas, and better performance relative to them is associated with improved outcomes (Hepner, Rowe et al. 2007). To date, collaborative care approaches remain the only identified method for enhancing guideline concordance, and improving outcomes, in primary care. It is thus essential for primary care and mental health specialist managers to know which features of collaborative care research interventions are necessary for achieving effects.

Our study builds directly on a prior literature synthesis recently published by Williams et al. This study aimed at identifying features of collaborative care, but did not carry out quantitative or rigorous qualitative analyses to determine relationships between features and study outcomes.

The data set assembled by this study, however, provides a rigorously identified set of high quality collaborative care articles that follow a chronic illness care model. The authors assembled, in addition, a rich set of over 60 rigorously defined variables, of which 22 related to specific broad intervention or evaluation features. By using this set as a starting point, we aimed to focus this study intensively on understanding the links between features and outcomes.

While previous meta-analyses were aimed primarily at determining whether collaborative care models, loosely defined, were effective, Williams aimed specifically to understand collaborative care features. He and colleagues therefore selected a group of articles that were more homogeneous in design (all randomized trials) and that focused on an organizational intervention aimed at patients (eliminating studies limited to staff level interventions only, such as education or reminders). Selected studies (a) involved primary care patients receiving acute-phase treatment; (b) tested a multicomponent intervention involving at least one patient-directed component; and (c) reported effects on depression severity. Reviewers analyzed the 28 multifaceted organizational interventions meeting these criteria according to intervention features mapped to the Chronic Illness Care Model (Wagner, Austin et al. 2001). Reviewers sought further unpublished details from study authors as needed.

The review found that all selected studies involved care management and required additional resources or staff reassignment to implement. The other most commonly used features among the studies included: patient education and self-management, monitoring of depressive symptoms and treatment adherence, decision support for medication management, a patient registry and mental health supervision of care managers. Additional intervention features were highly variable. Overall, the set of studies selected confirmed prior meta-analysis results, showing significant short-term effects of collaborative care up to 12 months and with three studies showing longer-term effects (up to 57 months). No quantitative analyses relating features to outcomes were performed, however. The study concluded that there was strong evidence supporting the benefits of care management for depression, but only “emerging” evidence on what constituted a successful care management model.

## METHODS

### Topic Development

The Veterans Health Administration (VHA), along with many other health care organizations and primary care practices, aims to improve care for depression among primary care patients. VHA participated in the President’s New Freedom Commission, and developed mental health strategic priorities related to improving mental health care in primary care in 2004 based in part on the Commission’s report. Following the strategic plan goals, beginning in 2006, VHA began a series of initiatives focusing on primary care/mental health integration, funded at high levels and culminating in a mandatory Uniform Mental Health Services Package for mental health conditions (VHA Handbook 1160.01). In beginning the improvement process, VHA researchers and policy makers identified the need to understand in more depth which of the features of previously tested multifaceted depression care interventions might be considered optional, and which should be considered required based on their impacts on outcomes. Required features could be incorporated into guidelines or best practices for improvement, and could be targeted for particular attention, tools, and other resources during the implementation of the improvements in new organizations and practices.

Our main research question was whether, based on the literature, there are specific features of rigorously evaluated depression care improvement interventions that characterize effective interventions or are associated with greater intervention impacts. As a secondary research question, we asked whether there were specific design features of the practice settings or of the evaluation designs in these studies that might be associated with consistently greater or smaller effects. We also assessed effects of patient complexity on intervention effectiveness.

## METHODOLOGICAL OVERVIEW

In this study, we used the Williams review (Williams, Gerrity et al. 2007) as the basis for further investigation of relationships between intervention features, study designs, and outcomes. We used the 28 selected studies, and the 22 specific variables already abstracted to describe intervention or evaluation features, as the basis for quantitative evaluation. We developed hypotheses about features most likely to affect outcomes, and used existing variables, derived variables based on them, or new variables created for this review to address these hypotheses. We re-abstracted articles and queried authors to complete new variables. All new variables represented independent review and consensus among three investigators (JW, LR, MS). After reviewing quantitative results, we used qualitative cross-case impact analysis (Miles and Huberman 1994) iteratively with quantitative regression analysis to refine our results and develop a short list of key intervention features.

## SEARCH STRATEGY

The search strategy used in the Williams review (Williams, Gerrity et al. 2007) is listed below:

DATABASE SEARCHED & TIME PERIOD COVERED: We searched Medline, HealthSTAR, CINAHL, PsycINFO and a specialized registry of depression trialsfor English-language medical literature published from 1966 to February 2006

LIMITERS:

SEARCH STRATEGY: Search terms included: (a) the MESH terms “depressive disorder” and “depression”; (b) a series of terms validated to identify clinical trials; and (c) a series of MESH terms and text words designed to identify studies using one or more elements of care management (Appendix A). Other sources were references identified from pertinent articles and contacts with experts in the field of depression and health services interventions. Exact search terms are reported in (Williams, Gerrity et al. 2007).

In addition to our PubMed search, we performed reference mining of retrieved articles, references of prior reviews, and solicited articles from experts.

NUMBER OF ITEMS RETRIEVED: 1464

## STUDY SELECTION

Of 1464 articles identified, reviewers from the Williams study (Williams, Gerrity et al. 2007) identified 138 as potentially relevant. These were reviewed to identify randomized controlled trials meeting the following selection criteria: (a) samples comprising adult patients with a depressive disorder who were cared for in a primary care setting; (b) interventions needed to augment usual care by incorporating at least one patient-directed element from the CCM (e.g., patient self-management, active follow-up); and (c) studies had to report clinically meaningful outcomes, such as change in depressive symptoms. Interventions directed solely at the clinician (e.g., clinician education or performance feedback) or health care system (e.g., automated clinical reminders) were not included. Twenty-eight of the 136 articles met these criteria.

## DATA ABSTRACTION

Our final set of key intervention variables, and their definitions, is listed in Table 1. Some variables are from the original Williams study (Williams, Gerrity et al. 2007). Others are based on either re-derivation or re-abstraction as a part of this study. Table 1 provides the variable labels, names and definitions for the major analytic variables. It also indicates whether the distribution of each variable was adequate for regression analysis (at least 3 studies per variable value) at each time period (short-term, medium-term or long-term). Variables measuring non-white status and comorbidity are listed in Table 7 only.

Table 1 Variables Characterizing the Study Intervention and Design

VARIABLE NAME | VARIABLE DEFINITION AND DISTRIBUTION^†^
Number of Practices in the Study (practice group = small, medium, or large) | Number of practices in the study. There are three levels: Small (1–2); Medium = (3–10); Large = (>10). (categorical) Distribution adequate for short-term and intermediate-term. Inadequate for long-term based on too few “small” category studies.
Referred to the Study by Primary Care Clinicians or on Antidepressant Medications (type_ref1=yes) | Patients enrolled in the study were referred by primary care clinicians and/or were on antidepressant medications. All other studies screened patients for depression, and included those who screened in as probably depressed. (dichotomous) Distribution adequate for short-term, intermediate-term and long-term.
Referred to the Study by Primary Care Clinicians and on Antidepressant Medications or Willing to Take Them. (type_ref2=yes) | Patients enrolled in the study were referred by primary care clinicians and were on antidepressant medications or indicated a willingness to start them. Distribution adequate for short-term and intermediate-term; inadequate for long-term based on too few “yes” category studies.
Study Set in Primary Care Clinician Offices (type_set=yes) | Study set in primary care clinician offices rather than in a community-based setting. (dichotomous) Distribution not adequate for short-term, intermediate-term or long-term based on too few “no” category studies.
Patient Level Randomization (rand1=yes) | Subjects were randomized at the patient level rather than at the provider or practice level (dichotomous) Distribution adequate for short-term, intermediate-term and long-term.
Structured Care Manager Assessment of Depression Symptoms (Baseline and Follow-up) and Treatment Adherence (CMAssess= yes)^*^ | Depression Care Manager (DCM) assesses depression symptoms with a structured instrument at baseline and at one or more follow-up visits; and also assesses treatment adherence (dichotomous) Distribution adequate for short-term and intermediate-term but not for long-term, based on too few “no” category studies.
Active Self-Management Support (self_manage = yes)) | Facilitates active self-management (goal-setting and/or patient activation), provides patient education, and encourages adherence to plan and tracking of progress (dichotomous) Distribution adequate for short-term, intermediate-term and long-term.
Care Manager Triage to Mental Health (MH_spec=yes) | DCM guided patients to mental health specialty instead of primary care based on preferences, symptoms, comorbidities, or other clinical judgment (dichotomous) Distribution adequate for short-term, intermediate-term and long-term.
Primary Care Clinician Adjusts Antidepressants (MedAdjR=yes) | Primary care clinician adjusted antidepressant medications with review and input as needed from a mental health specialist or other depression medication expert (dichotomous) Distribution adequate for short-term and intermediate-term, but not for long-term, based on too few “no” category studies.
Care Managers are Medical Nurses (CMMedNurse=yes) | Care managers were predominantly medical nurses rather than psychiatric nurses, other mental health professionals, pharmacists, or health educators (dichotomous) Distribution adequate for short-term, intermediate-term and long-term.
Intensity of Intervention Assessment and Follow-Up (robustness=high, medium, or low) | Intensity is defined by three features: (1) DCM structured assessment of depression symptoms (baseline and follow-up) and treatment adherence, (2) adequate number ( mean of >3) of DCM contacts, and (3) antidepressant adjustment by the primary care clinician with expert guidance. The three levels of intensity are based on having one, two, or three features (categorical) Distribution adequate for short-term, but not for intermediate-term or long-term based on too few “medium” category studies.
Classic Collaborative Care Intervention With Long Follow-up (type_int1= yes) | Has care management by an RN or doctoral level pharmacist, primary care clinician collaboration with mental health specialty, patient education, and follow-up for at least 16 weeks (either by telephone or in person) (dichotomous) Distribution adequate for short-term, intermediate-term and long-term.
Active Patient Follow-up for At Least 16 Weeks (_16_weeks = yes) | Intervention included at least 16 weeks of active patient follow-up (dichotomous) Distribution adequate for short-term, but not for inter-mediate-term or long-term based on too few “no” category studies.
Overall Intervention Impact (impact = high (1), medium (2), low (3), little or no (4)) | Independent judgment regarding how certain and how large the impact of the intervention was by two reviewers blinded to study methods or results (viewing extracted study out- comes only). Raters identified four levels of impact (high, medium, low, and little or no impact). Judgments were based on effect size/significance of intervention impact on depression symptoms, process of care, patient satisfaction, and overall quality of life, considering all time points. (categorical) Distribution adequate for short-term, but not for inter-mediate-term or long-term. This is based on too few “3” category studies for medium-term and too few “ 2” & “3” categories for long-term.
Type of Self-Management Support [A = Active (use of behaviorally-oriented techniques), P = Passive (educational materials without personal contact), N = No evidence of self-management support) | Intervention included self-management support or there was no evidence of self-management support. Support was either active or passive. Used only for qualitative analysis (categorical).
Primary Care Clinicians Are Involved (PCP_Involve = yes) | The intervention specified that primary care clinicians be actively involved in decision-making on depression management, rather than delegating decision-making to others after initial referral to collaborative care (dichotomous). Distribution not adequate for short-term, intermediate-term or long-term based on too few “no” category studies.
Mental Health Specialists are Involved (MH_Specialty = yes) | The intervention specified that one or more mental health specialists be actively involved in monitoring patients, either directly or through communication with the primary care clinician or care manager, after initial referral to collaborative care. (dichotomous). Distribution not adequate for short-term, intermediate- term or long-term based on too few “no” category studies.
Standardized Care Manager Baseline Symptom Assessment (CM_Staff_Base_Sx = yes)^**^ | Dedicated care manager staff conducted assessment of patient symptoms at baseline using a standardized scale. By dedicated, we mean an individual who carried out this function as a defined, discrete job, rather than e.g. a primary care clinician or pharmacist engaged in usual practice. Usually studies also indicated specific training (dichotomous). Distribution not adequate for short-term, intermediate- term or long-term based on too few “no” category studies.
Standardized Care Manager Follow-up Symptom Assessment (CM_Staff_F_U_SX = yes)^***^ | Dedicated care manager staff conducted followed up assessments of patient symptoms using a standardized scale. By dedicated, we mean an individual carried out this function as a defined, discrete job. Usually studies also indicated specific training (dichotomous). Distribution adequate for short-term, but not medium- term or long-term based on too few “no” category studies.
Care Manager Follow-up of Treatment Adherence (CM_Staff_F_U_Adh = yes)^****^ | Dedicated care manager staff F\followed patients proactively for treatment adherence. By dedicated, we mean an individual who carried out this function as a defined, discrete job. Usually studies also indicated specific training (dichotomous). Distribution not adequate for short-term, intermediate- term or long-term based on too few “no” category studies.

* CMAssess2 same as CMAssess except that the Dietrick article is coded as “yes” rather than “9” for base symtoms

** Same coding as BaseSx except that the Dietrick article is coded as “yes” rather than “9”

*** Same coding as DepScale

**** Same coding as TxAdhere

† Adequacy of variable distribution is based on having at least three studies with each variable value, see analysis methods. Short-term, medium-term, and long-term refer to time of measurement of effects, see outcome variable definitions. Intervention characteristics that were too prevalent in the sample to be investigated quantitatively and were therefore subjected to qualitative impact analysis are listed in bold.

Table 7 Qualitative Comorbidity Ranked by Overall Impact^*^

Study | Proportion with Major Depressive Disorder (MDD) | Proportion Non-White (Minority) | Exclude Substance abuse? (e_sa) | exclude dementia? (E_Dementia) | exclude ptsd? (E_PTSD) | exclude anxiety? (E_Anxiety) | exclude psychosis? ( E_Psychosis) | exclude bipolar disorder? (E_BD) | overall impact
| | | 1= yes 0= No | 1= yes 0= No | 1= yes 0= No | 1= yes 0= No | 1= yes 0= No | 1= yes 0= No | 1= High 2 = Medium 3 = Low 4 = Little or None
Araya | 1 | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 1
Katon 1995 | 0.419 | No Data | 1 | 1 | 9 | 0 | 1 | 1 | 1
Katon 1996 | 0.424 | 0.13 | 1 | 1 | 9 | 0 | 1 | 1 | 1
Katon 1999 | 0.798 | 0.17 | 1 | 9 | 9 | 0 | 1 | 1 | 1
Katon 2004 | 0.62 | 0.25 | 1 | 0 | 0 | 0 | 1 | 1 | 1
Katzelnick | 1 | 0.17 | 1 | 9 | 0 | 0 | 1 | 1 | 1
Simon 2004 | 0.59 | 0.2 | 0 | 0 | 0 | 0 | 1 | 1 | 1
Wells | 0.563 | 0.43 | 0 | 1 | 0 | 0 | 0 | 0 | 1
Unutzer | 0.69 | 0.245 | 1 | 1 | 0 | 0 | 1 | 1 | 1
Bruce | 0.662 | 0.33 | 0 | 1 | 0 | 0 | 0 | 0 | 2
Dietrich | 0.79 | 0.167 | 1 | 0 | 1 | 0 | 1 | 1 | 2
Hunkeler | - | 0.37 | 1 | 0 | 0 | 0 | 1 | 1 | 2
Oslin | 0.688 | 0.55 | 0 | 1 | 1 | 0 | 1 | 1 | 2
Peveler | 0.49 | No Data | 0 | 1 | 0 | 0 | 1 | 0 | 2
Rost | 0.774 | 0.157 | 1 | 9 | 9 | 9 | 0 | 1 | 2
Simon | - | No Data | 1 | 1 | 0 | 0 | 1 | 1 | 2
Datto | 0.847 | 0.2 | 1 | 9 | 9 | 9 | 1 | 1 | 3
Fortney | 0.82 | 0.253 | 1 | 1 | 0 | 0 | 1 | 1 | 3
Hedrick | 0.944 | 0.2 | 1 | 1 | 1 | 0 | 1 | 1 | 3
Waterreus | 0.24 | No Data | No Data | 0 | 0 | 0 | 0 | No Data | 3
Adler | 0.76 | 0.276 | 1 | 1 | 0 | 0 | 1 | 1 | 4
Brook | - | 0.01 | 0 | 0 | 0 | 0 | 0 | 0 | 4
Cappocia | 0.41 | 0.22 | 1 | 0 | 0 | 0 | 1 | 0 | 4
Dobscha | 0.49 | 0.05 | 0 | 1 | 0 | 0 | 1 | 1 | 4
Finley | - | No Data | 1 | 0 | 0 | 0 | 1 | 1 | 4
Mann | 0.82 | No Data | 0 | 0 | 0 | 0 | 0 | 1 | 4
Rickles | - | 0.08 | 0 | 0 | 0 | 0 | 1 | 1 | 4
Swindle | 0.88 | 0.142 | 1 | 1 | 9 | 9 | 1 | 1 | 4

* See Methods section for full description of the impact variable. See Table 1 for full descriptions of the remaining variables.

Variable Definition and Abstraction in the Williams Study: In the Williams study (Williams, Gerrity et al. 2007) pairs of independent reviewers (SKD, AJD, JWW, JD, TH, BNG) abstracted the 28 articles to identify features of the chronic illness care model (Wagner, Austin et al. 2001; Bodenheimer, Wagner et al. 2002; Bodenheimer, Wagner et al. 2002); study clinician and patient characteristics; 3) components of the intervention (decision support, self-management support, delivery system redesign including care management and enhanced mental health involvement, and clinical information systems), and support for implementing the intervention; 4) care management functions and process, and 5) outcomes. When key information was missing or unclear, investigators contacted the primary author for clarification; 22 of 24 authors contacted responded to our request. Two investigators (MSG, JWW) reviewed areas of disagreement. Final classification was based on the consensus of all investigators.

Data abstraction included study design features, including inclusion and exclusion criteria, and proportion of minorities in the study. The study also focused substantially on care management, defined as any systematic or structured management of patient care by a designated provider, and on patient outcomes. Specific abstracted features on care management included coordination and communication among treating health care providers, patient education, monitoring symptoms and adherence to treatment plans, self-management support, or psychological treatments (Katon, Von Korff et al. 2001; Oxman, Dietrich et al. 2002). Outcomes abstracted included the proportion of subjects who had a least a 50% decrease in depressive symptomatology or remission in symptoms based on a validated questionnaire, the mean change in depressive symptoms, and antidepressant adherence. Extensive variable tables are included in the Williams publication.

Study Intervention and Evaluation Variable Definition and Abstraction (Current Study): We reviewed, re-abstracted or re-defined variables from the Williams study related to four categories relevant to our research questions. The first category focused on study intervention features and patient characteristics. The second category focused on intervention features. The third category focused on measures of study impact, including depression symptoms, patient adherence to treatment, satisfaction, and global improvement or functioning. The fourth category focused on study design characteristics, including proportion of patients who were non-white, and inclusion and exclusion criteria.

We then derived ten new variables. Five of the new variables required re-abstraction of the article set, while the other five were new combinations of previous variable values. Variables we re-derived and/or re-reviewed included those related to 1) care management (defined as any systematic or structured management of patient care that included coordination and communication among treating health care providers); 2) patient education; 3) self-management support or psychological treatments; 4) monitoring of symptoms; 5) monitoring of adherence to treatment plans, and 6) impact.

We contacted authors for additional information as needed. Overall, between the original data collection and our final data collection effort, we attempted to contact all but two of the authors, and succeeded in getting a responses from all but one of those we attempted (26/28). We got information from each of these authors between one and four times (mean 2.1). Only one of the authors contacted was unable to supply the information we needed. In both the original and final data collection efforts, two investigators independently abstracted the articles and reviewed any area of disagreement. Final variable values in the original data set were based on the consensus of all investigators on that article, and in our additional data collection were based on consensus of two authors (Williams and Rubenstein). For final analyses, a third author (MS) reviewed variables we identified as significant.

Study Outcome Variable Definitions and Abstraction: We used effect sizes for depression symptom change and relative risk of depression resolution as our main outcome measures. Our statistician for this study (MS) independently abstracted the data needed to calculate both effect sizes for the continuous outcomes and risk ratios for the dichotomous outcomes.

Our symptom outcome variables identified all reported effect sizes in short (six weeks to four months), medium (five to eight months), and long (nine to twelve months) time strata after baseline. We developed one set of outcome variables with values at these time periods based on continuous symptom measures, and another set based on dichotomous outcomes. Examples of continuous outcomes include results based on depression scales such as the Beck Depression Inventory, Hamilton Depression Rating Scale, or Hopkins Symptoms Checklist-20). Examples of dichotomous outcomes include assessments of the percent of patients recovered or below a specified symptom threshold by the end of the study.

After initial hypothesis testing, we developed and validated a newly-developed impact scale for subsequent qualitative and quantitative analyses. Because studies used different symptom measures and different follow-up time periods, each outcome variable based on effect size included only a portion of the articles in the set. To create an outcome measure applicable to all articles in the set, we developed an impact rating for each article.

To derive the impact measure, we randomly ordered the 28 studies on an Excel spreadsheet and listed only each study’s set of outcomes, without any other identifiers. We listed all of the measured outcomes for each study that fell into one of four conceptual domains. These were depression symptom outcomes, process of care outcomes (usually adherence to antidepressants), patient satisfaction, and quality of life or functioning (see table below). For each outcome we listed whatever statistics the authors reported. Two authors (LR and JW) then independently reviewed and rated the outcomes on the scrambled Excel spreadsheet, independently of any article identifiers. One investigator (JW) rechecked using outcomes from Table 4, Williams (Williams 2007). Considerations for assigning impact level included consistency of results across domains, size and significance of the effects, and persistence of results over time. The rating process graded impacts on a four-point scale as robust (high), medium, low, and none or negative. Interater reliability for impact judgments was high, with agreement on 86% (24/28) of ratings. Final impact ratings reflected consensus on the four studies rated differently. The example table below shows four actual example studies with their impact ratings.

## EXAMPLE TABLE FOR HOW IMPACT RATINGS WERE CARRIED OUT

Example Studies | Treatment Adherence (short-term) | Treatment Adherence (medium term) | Depression Symptoms (short term) | Depression Symptoms (medium or long term) | Satisfaction | Global or Functional impact | Impact Rating By LR, JW
Information recorded for each study, as available. Usual care group noted first vs. intervention group | E.g., odds ratios, significance, what was measured, time measured | E.g., odds ratios, significance, what was measured, time measured | E.g., odds ratios, change scores, significance, patients with 50% symptom decrease, type of measure, | E.g., odds ratios, change scores, significance; patients with 50% symptom decrease; type of measure | E.g., odds ratios, percent satisfied, significance, time measured | E.g., odds ratios, significance, what was measured | Robust, Moderate, Weak, Little or No Impact
#1 | --- | ---- | −3.9 vs −5.6, p= .02, Ham-D change, 3 mos. | −4.0, vs −7.3 p<.001, Ham-D change, 6 mos. 33% vs, 53% p<.001, Ham-D 50% improvement, at 12 mos. | ---- | P < .05 on the SF 20 at 12 mos., exact score not given | Robust
#2 | 957 vs 867, NS, Mean milligrams antidepressant dispensed at 6 wks | 2267i vs. 2111, NS, Mean milligrams antidepressant dispensed at 6 mos | 33% vs 38%, p=.01, Ham-D 50% improvement, at 6 weeks 33% vs 38%, NS, Beck 50% improvement, at 6 wks. | 38% vs. 57%, p=.003, Ham-D 50% improvement at 6 mos. 37% vs. 48%, p = .05, Beck 50% improvement at 6 wks. | 3.94 vs. 4.20, p=.001, 11 item unpublished scale, at 6 mos. | 44.6 vs. 47.3, p = .10, SF-12 MCS score at 6 mos. | Moderate
#3 | -- | 42% vs 64%., p<.001, prescribed ≥90 days AD | 1.5 vs. 1.58, NS, SCL-20, at six months | 1.63 vs. 1.62 NS, SCL-20, at six months | --- | 31.7 vs. 31.1, NS, PCS from SF36V | Weak
#4 | No significant difference at 3 mos. (no numeric data provided) | 30% versus 49% adherent to anti-depressants, p ≤.05, at six months excluding 3 dropouts, NS for intent to treat | 21% vs. 21% 50% improvement, NS, BDI, 3 mos. | --- | --- | ---- | Weak

## STUDY QUALITY ASSESSMENT

Determination of study quality was based on the Williams study. The quality measure took account of the process of randomization and allocation concealment, fidelity to the planned intervention without significant co-intervention, follow-up rates and analytic methods, using an intent-to-treat approach and blinded outcome assessments. Based on these criteria, risk of bias was rated as a low (all elements met), moderate (> 1 element partially met), or high (> 1 element not met) (Higgins and Green). There were no disagreements about quality assessments.

## DATA SYNTHESIS AND ANALYSIS

Correlations: Prior to carrying out regression analysis, we evaluated correlations between intervention and evaluation design features. Since intervention and evaluation features were categorical, we evaluated the correlations between variables using cross tabulations and the chi-square statistic.

Effect Size Calculations for Continuous Outcomes: In order to compare estimates across studies that report different depression scales, the effect size was selected as the unit of analysis. An effect size was calculated if the follow-up mean, standard deviation, and sample size for both the intervention group and usual care group were reported or could be calculated. For trials that reported a mean outcome but no standard deviation, the standard deviation was estimated by taking the mean standard deviation weighted by the sample size across all other trials that reported standard deviations for that outcome (Furukawa, 2006).

Only one comparison per study within each time strata was calculated. For studies that included more than one intervention group, the group that was most similar to the complete collaborative care model was included. In addition, only one outcome per study was used. If a study reported more than one depression scale, then the measure that was clinically homogeneous to the scales reported in the other included studies was selected. Effect sizes were calculated by dividing the difference of follow-up means of the intervention and control group by the pooled follow-up standard deviations of the two groups (Sutton AJ, 2000). Ninety-five percent confidence intervals were calculated for each effect size. A negative effect size indicates that the intervention group did better at follow-up than the control group. Negative effect sizes indicate benefit because when the intervention group is doing better than the control group, depression symptoms are reduced. Thus, for example, for each independent variable, the largest negative effect size shows the group with the greatest effect.

Risk Ratio Calculations for Dichotomous Outcomes: We estimated a risk ratio to assess effect for dichotomous variables. For the risk ratio analysis, we used the longest follow-up interval reported. Risk ratios and their ninety-five percent confidence intervals were estimated for studies that reported the percent of people who improved since baseline in each study. A risk ratio greater than one indicates that the intervention group had a higher rate of improvement than the usual care group did. For example, a risk ratio of 1.50 signifies that 50% more people improved in the intervention group than in the usual care group. All analyses were conducted in Stata version 10.0.

Quantitative analysis focused on assessing key independent variables related to evaluation or implementation design against depression symptom outcomes as the dependent variable. Correlations between the independent variables were assessed. A stratified meta-regression was conducted separately for each independent variable with the effect size as the outcome (Sutton AJ, 2000). Stratification was based on follow-up time. A study could contribute to more than one stratum. Bivariate meta-regressions using the same independent variables as above were also conducted using the risk ratio as the outcome. Estimates were obtained from the meta-regessions for each level of the independent variable. In most cases, the independent variables had two levels (e.g. did the study have the component or not). A z-test was used from the meta-regression to test if the difference in effect sizes or risk ratios was significant between component groups. Differences with p-values less than 0.05 were denoted (Stata, 2006).

In this study, we found variations in which outcomes were used, ranging from a variety of depression symptom indices, health-related quality of life, patient satisfaction, and process of care for depression. We also found variations in when outcomes were measured. We used a conservative analytic approach such that we focused on depression symptom outcomes only. We also focused on time frames separately, rather than combining results across time frames.

## QUALITATIVE ANALYSIS

We carried out qualitative cross-case analysis using methods based on Miles and Huberman (Miles and Huberman 1994). We used this approach to overcome limitations to meta-regression in our article sample primarily the inability to include all 28 selected articles in a single meta-regression analysis. In traditional meta-analysis, the study intervention is treated as the same across all studies. The major challenges posed during this kind of analysis derive from variations in how outcomes are reported (e.g. by time period, or specific measure); these variations may limit the number of studies included in a given analysis. However, since each study is included as a whole, power for detecting overall effects with an article sample size like ours is generally adequate. Meta-regression, however, makes comparisons within the overall group of studies and is thus more analytically demanding. In addition, valid meta-regression using multiple features or control variables simultaneously would require more studies than were available to us. Since no single quantitative outcome analysis in this study included all reviewed studies, we wanted to confirm qualitatively that our quantitative results were insensitive to inclusion of all studies in the same outcome analysis. We also wanted to be able to assess intervention features that characterized too many studies in the sample to be tested quantitatively (see Table 1). Cross-case analysis afforded us the ability to achieve these goals.

To carry out the analyses, we ranked studies by impact level based on our overall impact measure (see above). We focused primarily on the intervention features that had inadequate distributions either at all time periods or at medium-term and long-term due to being present in too many studies in the sample (see Table 1). These intervention characteristics could not be adequately tested quantitatively. We also developed four main scenarios based on our hypotheses for types of interventions or design features and their relationships to impact. We then created a series of tables around these scenarios as antecedent matrices related to our conceptual model of collaborative care and our hypotheses about effects of study design features. We looked for patterns, and verified scenarios for similar and contrasting outcomes.

## PEER REVIEW

This report was reviewed by our technical experts. Their comments were taken into consideration in our revision. Service as a technical expert does not imply endorsement of the report’s findings. A table of peer review comments received and the changes we made to the report is presented in Appendix B.