# Selected Studies

Study | Organization (practices) | Study Quality
Study | Organization (practices) | n | Analysis (follow-up rate) | Blinding outcomes assessment | Risk of bias
Adler et al., 2004 | Academic and community (9 practices; 53 clinicians) | 507 | Intent-to-treat (3 months, 73%; 6 months, 76%) | Yes | Low
Araya et al., 2003 | 3 Clinics, Santiago, Chile (clinicians, NS) | 240 | Intent-to-treat (3 months, 88%; 6 months, 88%) | Yes | Low
Brook et al., 2005 | General practice, The Netherlands (19 community pharmacists; clinicians not involved) | 135 | Intent-to-treat (3 months, 88%; 6 months, 81%) | Yes | Moderate
Bruce et al., 2004 | (20 Community practices; number of clinicians, NS) | 598 | Intent-to-treat (4 months, 82%; 8 months, 76%; 12 months, 69%) | Yes | Low
Capoccia et al., 2004 | Academic family practice clinic (20 staff physicians; 18 trainees; 4 Physician Assistants) | 74 | Intent-to-treat (3 months, 96%; 6 months, 95%; 9 months, 95%; 12 months, 93%) | Yes | Low
Datto et al., 2003 | University-affiliated (35 practices; 151 clinicians) | 61 | Completers (6 months, 86%) | No | High
Dietrich et al., 2004 | 5 Health care organizations (60 practices; 226 clinicians) | 405 | Intent-to-treat (4 months, 82%; 8 months, 76%; 12 months, 69%) | Yes | Low
Dobscha et al., 2006 | Veterans Affairs (5 practices; 41 clinicians) | 375 | Intent-to-treat (6 months, 84%; 12 months, 85%) | Yes | Low
Finley et al., 2003 | Staff model HMO (1 practice; 30 clinicians) | 125 | Completers (6 months, 67%) | Yes | High
Fortney et al., 2006 | Veterans Affairs: community clinics (7 clinics) | 395 | Intent-to-treat (6 months, 91%; 12 months, 85%) | Partially met | Moderate
Hedrick et al., 2003 | Veterans Affairs (4 firms; 89 clinicians) | 354 | Intent-to-treat (3 months, 92%; 9 months, 92%) | Yes | Low
Hunkeler et al., 2000 | Staff model HMO (2 practices; 100 clinicians) | 302 | Completers (6 weeks, 90%; 6 months, 85%) | NS | Moderate
Katon et al., 1995 | Staff model HMO (1 practice; 22 clinicians) | 217 | Completers (4 months, 89%; 7 months, 85%) | Yes | Moderate
Katon et al., 1996 | Staff model HMO (1 practice; 22 clinicians ) | 153 | Intent-to-treat (4 months, 84%; 7 months, 76%) | Yes | Low
Katon et al., 1999 | Staff model HMO (4 practices; 73 clinicians) | 228 | Intent-to-treat (3 months, 85%; 6 months, 84%; 28 months, 75%) | Yes | Low
Katon et al., 2004 | Staff model HMO (9 practices) | 329 | (3 months, 93%; 6 months, 89%; 12 months, 88%) | Yes | Low
Katzelnick et al., 2000 | 3 HMOs (practices, NS; 163 clinicians) | 407 | Intent-to-treat (3 months, 94%; 6 months, 94%; 12 months, 93%) | Yes | Low
Mann et al., 1998 | General practice, (19 practices) | 419 | Intent-to-treat (4 months, 92%) | No | High
Oslin et al., 2003 | Veterans Affairs (4 practices; 37 clinicians) | 97 | Intent-to-treat (4 months, 76%) | Yes | Low
Peveler et al., 1999 | General practice, (28 practices; 47 clinicians) | 213 | Intent-to-treat (6 weeks, 97%; 3 months, 96%) | Yes | Low
Rickles et al., 2005 | (14 Community pharmacists; 60 clinicians) | 63 | Intent-to-treat (3 months, 95%) | Yes | Moderate
Rost et al., 2001 | (12 Community practices; 24 clinicians) Mixed (8 systems; | 479 | Intent-to-treat (6 months, 90%; 24 months, 67%) | Yes | Low
Simon et al., 2000 | Staff model HMO (5 practices; 40–50 clinicians) | 613 | Intent-to-treat (3 months, 97%; 6 months, 96%; 60 months, 73%) | Yes | Low
Simon et al., 2004 | Staff model HMO (7 practices) | 600 | Intent-to-treat (6 months, 89%; 18 months, 85%) | Yes | Low
Swindle et al., 2003 | Veterans Affairs (2 firms; 23 clinicians; 100 trainees) | 268 | Completers (3 months, 92%; 6 months, 83%) | NS | High
Unutzer et al., 2002 | 18 practices; 367 clinicians) | 1801 | Intent-to-treat (3 months, 90%; 6 months, 87%; 12 months, 83%) | Yes | Low
Waterreus et al., 1994 | General practice, London, UK (practices, NS; 25 clinicians) | 96 | Completers (3 months, NS; 6 months, NS; 12 months, NS) | Yes | Moderate
Wells et al., 2000 | Staff model and network-managed care (46 practices; 181 clinicians) | 1356 | Intent-to-treat (6 months, 85%; 12 months, 83%) | Yes | Low