# REFERENCES

1 Veterans Health Administration Office of the Assistant Deputy Under Secretary for Health for Policy and Planning. Projections of the prevalence and incidence of dementias including Alzheimer's Disease for the total, enrolled, and patient veteran populations aged 65 or over. 2004. http://www4.va.gov/HEALTHPOLICYPLANNING/reports1.asp.
2 Teri L, Logsdon RG, McCurry SM. Nonpharmacologic treatment of behavioral disturbance in dementia. Med Clin North Am. 2002. May. 2002;86(3):641-656. [pmid: 12168563].
3 Zetteler J. Effectiveness of simulated presence therapy for individuals with dementia: a systematic review and meta-analysis. Aging Merit Health. Nov. 2008;12(6):779-785.
4 National Institute for Health and Clinical Excellence (NICE). Dementia: A NICE-SCIE Guideline on supporting people with dementia and their careers in health and social care, National Clinical Practice Guideline Number 42. Vol: The British Psychological Society and Gaskell. 2007.
5 Opie J, Rosewarne R, O'Connor DW. The efficacy of psychosocial approaches to behaviour disorders in dementia: a systematic literature review. Aust N Z J Psychiatry. Dec. 1999;33(6):789-799. [pmid: 10619204].
6 McDonagh MS, Peterson K, Carson S, Chan B, Thakurta S. Drug class review on atypical antipsychotic drugs, Update #2 final report. http://www.ohsu.edu/drugeffectiveness/reports/final.cfm. 2009.
7 Ayalon L, Gum AM, Feliciano L, Arean PA. Effectiveness of nonpharmacological interventions for the management of neuropsychiatric symptoms in patients with dementia: a systematic review. Arch Intern Med. Nov. 13. 2006;166(20):2182-2188. [pmid: 17101935].
8 Goy E, Freeman M, Kansagara D. A systematic evidence review of interventions for non-professional caregivers of patients with dementia, A report by the Evidence-based Synthesis Program of Veterans Health Administration, Health Services Research & Development. Washington, DC. May. 2009.
9 Brozek JL, Akl EA, Alonso-Coello P, et al. Grading quality of evidence and strength of recommendations in clinical practice guidelines. Part 1 of 3. An overview of the GRADE approach and grading quality of evidence about interventions. Allergy. May. 2009;64(5):669-677. [pmid: 19210357].
10 Woods B, Spector AE, Jones CA, Orrell M. Davies SP Reminiscence therapy for dementia. Cochrane Database of Systematic Reviews. 2009;(3).
11 Livingston G, Johnston K, Katona C, Paton J, Lyketsos CG, Old Age Task Force of the World Federation of Biological P. Systematic review of psychological approaches to the management of neuropsychiatric symptoms of dementia. Am J Psychiatry. Nov. 2005;162(11):1996-2021. [pmid: 16263837].
12 O'Connor DW, Ames D, Gardner B, King M. Psychosocial treatments of psychological symptoms in dementia: a systematic review of reports meeting quality standards. Int Psychogeriatr. Apr. 2009;21(2):241-251. [pmid: 19138459].
13 O'Connor DW, Ames D, Gardner B, King M. Psychosocial treatments of behavior symptoms in dementia: a systematic review of reports meeting quality standards. Int Psychogeriatr. Apr. 2009;21(2):225-240. [pmid: 18814806].
14 Neal M, Barton Wright P. Validation therapy for dementia. Cochrane Database of Systematic Reviews. 2009;(3).
15 Weina P, Zhao H, Zhishun L, Shi W. Acupuncture for vascular dementia. Cochrane Database of Systematic Reviews. 2009;(2).
16 Holt FE, Birks TPH, Thorgrimsen LM, Spector AE, Wiles A, Orrell M. Aroma therapy for dementia. Cochrane Database of Systematic Reviews. 2009;(3).
17 Forbes D, Morgan DG, Bangma J, Peacock S, Adamson J. Light Therapy for Managing Sleep, Behaviour, and Mood Disturbances in Dementia. Cochrane Database of Systematic Reviews. 2009;(3).
18 Hansen NV, Jorgensen T, Ortenblad L. Massage and touch for dementia. Cochrane Database of Systematic Reviews. 2009;(3).
19 Gleeson M, Timmins F. The use of touch to enhance nursing care of older person in long-term mental health care facilities. Journal of Psychiatric & Mental Health Nursing. Oct. 2004;11(5):541-545. [pmid: 15450020].
20 Cuddy LL, Duffin J, Cuddy LL, Duffin J. Music, memory, and Alzheimer's disease: is music recognition spared in dementia, and how can it be assessed?. Med Hypotheses. 2005;64(2):229-235. [pmid: 15607545].
21 Braben I. A Song for Mrs. Smith. Nursing Times. 1992;88(41):54. [pmid: 1491979].
22 Swartz KP, Hantz EC, Crummer GC, Walton JP, Frisina RD. Does the melody linger on? Music cognition in Alzheimer's disease. Semin Neurol. Jun. 1989;9(2):152-158. [pmid: 2690246].
23 Brotons M, Koger SM, Pickett-Cooper P. Music and dementias: A review of literature. Journal of Music Therapy. Win. 1997;34(4):204-245.
24 Vink AC, Birks J, Bruinsma MS, Scholten RJPM. Music therapy for people with dementia. Cochrane Database of Systematic Reviews. 2009;(3).
25 Sung HC, Chang AM. Use of preferred music to decrease agitated behaviours in older people with dementia: a review of the literature. J Clin Nurs. Oct. 2005;14(9):1133-1140. [pmid: 16164531].
26 Sherratt K, Thornton A, Hatton C. Music interventions for people with dementia: A review of the literature. Aging & Mental Health. Jan. 2004;8(1):3-12. [pmid: 14690862].
27 Clark ME, Lipe AW, Bilbrey M. Use of music to decrease aggressive behaviors in people with dementia. J Gerontol Nurs. Jul. 1998;24(7):10-17. [pmid: 9801526].
28 Gerdner LA. Effects of individualized versus classical “relaxation” music on the frequency of agitation in elderly persons with Alzheimer's disease and related disorders. International Psychogeriatrics. Mar. 2000;12(1):49-65. [pmid: 10798453].
29 Groene RW. Effectiveness of music therapy 1:1 intervention with individuals having senile dementia of the Alzheimer's type. Journal of Music Therapy. 1993;30(3):138-157.
30 Ragneskog H, Brane G, Karlsson I, Kihlgren M. Influence of dinner music on food intake and symptoms common in dementia. Scand J Caring Sci. 1996;10(1):11-17. [pmid: 8715781].
31 Chung JCC, Lai CKY. Snoezelen for dementia. Cochrane Database of Systematic Reviews. 2009;(3).
32 Verkaik R, van Weert JC, Francke AL. The effects of psychosocial methods on depressed, aggressive and apathetic behaviors of people with dementia: a systematic review. Int J Geriatr Psychiatry. Apr. 2005;20(4):301-314. [pmid: 15799081].
33 Johnson MI. Electrotherapy: Evidence-Based Practice. Watson T, editor. Elsevier. 2008.
34 Cameron MH, Lonergan E, Lee H. Transcutaneous Electrical Nerve Stimulation (TENS) for dementia. Cochrane Database of Systematic Reviews. 2009;(3).
35 Logsdon RG, McCurry SM, Teri L. Evidence-based psychological treatments for disruptive behaviors in individuals with dementia. Psychol Aging. 03. 28. 2007. 2007;22:28-36. [pmid: 17385980].
36 Proctor R, Burns A, Powell HS, et al. Behavioural management in nursing and residential homes: a randomised controlled trial. Lancet. Jul. 3. 1999;354(9172):26-29. [pmid: 10406361].
37 Teri L, Gibbons LE, McCurry SM, et al. Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. JAMA. Oct. 15. 2003;290(15):2015-2022. [pmid: 14559955].
38 Teri L, McCurry SM, Logsdon R, et al. Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. Dec. 2005;45(6):802-811. [pmid: 16326662].
39 Teri L, Huda P, Gibbons L, et al. STAR: a dementia-specific training program for staff in assisted living residences. Gerontologist. Oct. 2005;45(5):686-693. [pmid: 16199404].
40 Gitlin LN, Winter L, Dennis MP, et al. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. Sep. 1. 2010;304(9):983-991. [pmid: 20810376].
41 Beck CK, Vogelpohl TS, Rasin JH, et al. Effects of behavioral interventions on disruptive behavior and affect in demented nursing home residents. Nurs Res. Jul-Aug. 2002;51(4):219-228. [pmid: 12131234].
42 Suhr J, Anderson S, Tranel D. Progressive Muscle Relaxation in the Management of Behavioural Disturbance in Alzheimer's Disease. Neuropsychological Rehabilitation. 1999;9(1):31-44.
43 McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-214. [pmid: 9988292].
44 Teri L, Logsdon RG, Uomoto J, McCurry SM. Behavioral treatment of depression in dementia patients: a controlled clinical trial. J Gerontol B Psychol Sci Soc Sci. Jul. 1997;52(4):P159-166. [pmid: 9224439].
45 Teri LP, Gibbons LEP, McCurry SMP, et al. Exercise Plus Behavioral Management in Patients With Alzheimer Disease: A Randomized Controlled Trial. JAMA. 2003;290(15):2015-2022. [pmid: 14559955].
46 Centre for Evidence Based Medicine. Levels of Evidence. March. 2009. http://www.cebm.net/index.aspx?o=1025. Feb. 15, 2011.
47 Libin A, Cohen-Mansfield J. Therapeutic robocat for nursing home residents with dementia: preliminary inquiry. Am J Alzheimers Dis Other Demen. Mar-Apr. 2004;19(2):111-116. [pmid: 15106392].
48 Greer KL, Pustay KA, Zaun TC, Coppens P. A comparison of the effects of toys versus live animals on the communication of patients with dementia of the Alzheimer's type. Clinical Gerontologist: The Journal of Aging and Mental Health. 2001;24(3-4):157-182.
49 Martindale BP. Effect of animal-assisted therapy on engagement of rural nursing home residents. American Journal of Recreation Therapy. 2008;7(4):45-53.
50 McCabe BW, Baun MM, Speich D, Agrawal S. Resident dog in the Alzheimer's special care unit. West J Nurs Res. Oct. 2002;24(6):684-696. [pmid: 12365768].
51 Edwards NE, Beck AM. Animal-assisted therapy and Nutrition in Alzheimer's disease. West J Nurs Res. Oct. 2002;24(6):697-712. [pmid: 12365769].
52 Richeson NE. Effects of animal-assisted therapy on agitated behaviors and social interactions of older adults with dementia. Am J Alzheimers Dis Other Demen. Nov-Dec. 2003;18(6):353-358. [pmid: 14682084].
53 Churchill M, Safaoui J, McCabe BW, Baun MM. Using a therapy dog to alleviate the agitation and desocialization of people with Alzheimer's disease. J Psychosoc Nurs Ment Health Serv. Apr. 1999;37(4):16-22. [pmid: 10218187].
54 Batson K, McCabe B, Baun MM, Wilson C. The effect of a therapy dog on socialization and physiological indicators of stress in persons diagnosed with Alzheimer's disease. Thousand Oaks, CA. Sage Publications, Inc. 1998.
55 Kongable LG, Buckwalter KC, Stolley JM. The effects of pet therapy on the social behavior of institutionalized Alzheimer's clients. Arch Psychiatr Nurs. Aug. 1989;3(4):191-198. [pmid: 2774672].
56 Forbes D, Forbes S, Morgan DG, Markle-Reid M, Wood J, Culum I. Physical activity programs for persons with dementia. Cochrane Database of Systematic Reviews. 2009;(3).
57 Eggermont LH, Scherder EJ. Physical activity and behaviour in dementia: A review of the literature and implications for psychosocial intervention in primary care. Dementia: The International Journal of Social Research and Practice. Aug. 2006;5(3):411-428.
58 Heyn P, Abreu BC, Ottenbacher KJ. The effects of exercise training on elderly persons with cognitive impairment and dementia: a meta-analysis. Arch Phys Med Rehabil. Oct. 2004;85(10):1694-1704. [pmid: 15468033].
59 Holliman DC, Orgassa UC, Forney JP. Developing an interactive physical activity group in a geriatric psychiatry facility. Activities, Adaptation and Aging. 2001;26(1):57-69.
60 Rolland Y, Pillard F, Klapouszczak A, et al. Exercise program for nursing home residents with Alzheimer's disease: a 1-year randomized, controlled trial. J Am Geriatr Soc. Feb. 2007;55(2):158-165. [pmid: 17302650].
61 Stevens J, Killeen M, Stevens J, Killeen M. A randomised controlled trial testing the impact of exercise on cognitive symptoms and disability of residents with dementia. Contemp Nurse. Feb-Mar. 2006;21(1):32-40. [pmid: 16594879].
62 Francese T, Sorrell J, Butler FR. The effects of regular exercise on muscle strength and functional abilities of late stage Alzheimer's residents. American Journal of Alzheimer's Disease and Other Dementias. 1997;12(3):122-127.
63 Alessi CA, Yoon EJ, Schnelle JF, Al-Samarrai NR, Cruise PA. A randomized trial of a combined physical activity and environmental intervention in nursing home residents: do sleep and agitation improve?. J Am Geriatr Soc. Jul. 1999;47(7):784-791. [pmid: 10404920].
64 McCurry SM, Gibbons LE, Logsdon RG, et al. Nighttime insomnia treatment and education for Alzheimer's disease: a randomized, controlled trial. J Am Geriatr Soc. May. 2005;53(5):793-802. [pmid: 15877554].
65 Mulrow CD, Gerety MB, Kanten D, et al. A randomized trial of physical rehabilitation for very frail nursing home residents. JAMA. Feb. 16. 1994;271(7):519-524. [pmid: 8301766].
66 Van de Winckel A, Feys H, De Weerdt W, et al. Cognitive and behavioural effects of music-based exercises in patients with dementia. Clinical Rehabilitation. May. 2004;18(3):253-260. [pmid: 15137556].
67 Alessi CA, Martin JL, Webber AP, et al. Randomized, controlled trial of a nonpharmacological intervention to improve abnormal sleep/wake patterns in nursing home residents. J Am Geriatr Soc. May. 2005;53(5):803-810. [pmid: 15877555].
68 Baum EE, Jarjoura D, Polen AE, et al. Effectiveness of a group exercise program in a long-term care facility: a randomized pilot trial. Journal of the American Medical Directors Association. Mar-Apr. 2003;4(2):74-80. [pmid: 12807578].
69 Hermans D, Htay UH, McShane R. Non-pharmacological interventions for wandering of people with dementia in the domestic setting. Cochrane Database of Systematic Reviews. 2009;(3).
70 Price JD, Hermans D, Grimley Evans J. Subjective barriers to prevent wandering of cognitively impaired people. Cochrane Database of Systematic Reviews. 2009;(3).
71 Robinson L, Hutchings D, Corner L, et al. A systematic literature review of the effectiveness of non-pharmacological interventions to prevent wandering in dementia and evaluation of the ethical implications and acceptability of their use. Health Technol Assess. Aug. ix. 2006;10(26):iii-108. [pmid: 16849002].
72 Robinson L, Hutchings D, Dickinson HO, et al. Effectiveness and acceptability of non-pharmacological interventions to reduce wandering in dementia: a systematic review. Int J Geriatr Psychiatry. Jan. 2007;22(1):9-22. [pmid: 17096455].
73 Lauriks S, Reinersmann A, Van der Roest HG, et al. Review of ICT-based services for identified unmet needs in people with dementia. Ageing Res Rev. Oct. 2007;6(3):223-246. [pmid: 17869590].
74 Kong EH, Evans LK, Guevara JP. Nonpharmacological intervention for agitation in dementia: a systematic review and meta-analysis. Aging Ment Health. Jul. 2009;13(4):512-520. [pmid: 19629775].
75 Cohen-Mansfield J, Libin A, Marx MS. Nonpharmacological treatment of agitation: a controlled trial of systematic individualized intervention. J Gerontol A Biol Sci Med Sci. Aug. 2007;62(8):908-916. [pmid: 17702884].
76 Luijpen MW, Scherder EJ, Van Someren EJ, Swaab DF, Sergeant JA. Non-pharmacological interventions in cognitively impaired and demented patients–a comparison with cholinesterase inhibitors. Rev Neurosci. 2003;14(4):343-368. [pmid: 14640320].
77 American Veterinary Medical Association. Guidelines for Animal Assisted Activity, Animal-Assisted Therapy and Resident Animal Program. Current as of 2007. http://www.avma.org/issues/policy/animal_assisted_guidelines.asp.
78 Henderson NK, White CP, Eisman JA. The roles of exercise and fall risk reduction in the prevention of osteoporosis. Endocrinol Metab Clin North Am. Jun. 1998;27(2):369-387. [pmid: 9669143].
79 Carter ND, Kannus P, Khan KM. Exercise in the prevention of falls in older people: a systematic literature review examining the rationale and the evidence. Sports Med. 2001;31(6):427-438. [pmid: 11394562].
80 Inouye SK, Bogardus ST Jr, Charpentier PA, et al. A multicomponent intervention to prevent delirium in hospitalized older patients. N Engl J Med. Mar. 4. 1999;340(9):669-76. [pmid: 10053175].
81 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. Bmj. Jun. 19. 2004;328(7454):1490. [pmid: 15205295].