# DISCUSSION

Overall, clear and consistent evidence supporting the use of the various psychosocial therapies for the treatment of behavioral symptoms for dementia is lacking. Many reviews reported mixed results with little consistent evidence either favoring or rejecting the intervention in question. There are few good quality RCTs and much of the evidence comes from small scale studies often with great variability in how behavioral symptoms are defined, duration of intervention, measuring instruments, and the outcome measures used to determine the effectiveness of the various interventions.

The literature seems to suggest that stimulation or sensory-oriented approaches (i.e., light therapy, aromatherapy, and massage/touch therapy) show greater promise than emotion-oriented approaches, but there is little data directly comparing these approaches and this finding should be interpreted with caution given the overall limitations in the bodies of evidence. The sensory-oriented approaches may be cost-effective and somewhat easy to implement within VA settings, particularly because many can be implemented by a variety of care-giving personnel without advanced degrees. For instance, aromatherapy and hand massage therapy may be implemented in a communal setting with little caregiver training and most likely without incurring a high treatment cost.12

None of the emotion-oriented approaches was well-studied. Program implementation for all three – validation therapy, reminiscence therapy, and simulated presence therapy – require master's level personnel.

There is some evidence to suggest that behavior management techniques are effective strategies to reduce behavioral symptoms of dementia (see Table 1); however, the results of the reviewed studies must be interpreted with caution due to methodological limitations. In particular, inadequate blinding, usual care rather than alternative treatment control groups, and multiple measured outcomes in the reviewed studies result in questionable findings in need of replication. Though multiple outcomes can be beneficial in detecting treatment effects, the comparable outcomes assessed across studies resulted in conflicting findings, suggesting that some positive outcomes might be due to chance. This body of research documents a wide variety of techniques that are often individualized to patients; though this is a methodological limitation in that it is difficult to compare interventions and determine effective components, it is also a potential strength of behavior management techniques. These techniques are flexible and adaptable to various settings and patients, lending themselves toward individual tailoring rather than to a standardized population approach. Additional research using standardized behavior management interventions is needed to replicate initial findings across research labs and with a variety of populations. Finally, preliminary research on behavior management technique training for care providers suggests that these techniques could be implemented in a variety of settings with providers who do not have advanced degrees; it is likely that, given additional research documenting the efficacy of specific training programs, such programs could be implemented in VA settings in a relatively cost-effective manner.

Exercise therapy was evaluated in a number of trials, though, again, variations in intervention dose and population studied make it difficult to offer generalizable conclusions about its effectiveness. Exercise did seem consistently to increase sleep time in individuals with dementia. Though findings were mixed for other outcomes, it is possible that an increase in sleep time may be an important benefit in and of itself for both patients and caregivers. Some data suggest regular exercise may help improve mobility and decrease the risk of falls, which might suggest a useful "by-product" of exercise programs for cognitively impaired adults.78, 79 That cognitively impaired elderly adults are at increased risk of falls represents simultaneously a potential rationale for and risk of exercise programs. The proper intensity and frequency of exercise, along with the appropriate level of supervision required to minimize risk of falls, should be determined before exercise programs are implemented broadly in VA settings.

While it is important to evaluate the effectiveness of the various psychosocial interventions for behavioral symptoms of dementia with a wide range of participants and settings, it should be noted that there is also a need for individually tailored approaches. It is important to modify interventions to the specific needs and circumstances of the individuals with dementia, their caregivers, and their environment.4 Given the lack of certainty of overall benefit from these interventions, implemented programs should strive to minimize associated harms. For example, though sensory-oriented approaches did appear to offer some benefit to some intervention participants, an increase in agitation may occur in other participants. Because individual participants may respond differently to treatment, an iterative, flexible approach to program development seems critical.75 Some of the more recent studies investigating behavior management techniques39 and systematic individualized interventions75 provide preliminary evidence that targeted, tailored, and individualized approaches may be effective in decreasing certain behavioral symptoms of dementia; however, additional research replicated across research labs with adequate blinding of providers, raters, and participants is needed to strengthen this body of evidence.

There is much that remains unknown about the effectiveness and feasibility of non-pharmacological interventions. For instance, little is known about the potential harms from the various non-pharmacological treatments. Although the potential risk seems low, especially compared to the use of atypical and typical antipsychotic medication, few studies have included information on adverse events. Due to the potentially lesser risk associated with these techniques when compared with medication therapies, research documenting relative risk is warranted. In addition, as mentioned above, not all forms of psychosocial treatments for dementia may be appropriate for all patients. For example, simulated presence therapy has been shown to increase agitation and disruptive behaviors in some people while decreasing agitation in others.

Furthermore, it is unclear as to the extent to which patients may find certain therapies pleasurable in terms of duration and frequency. For instance, aromatherapy may be a pleasurable event when experienced for a short duration during a specific activity, but may cease to have an impact when patients are exposed on a continual basis or too frequently.

In addition, in cases where no treatment was used as the control, it is not clear if the simple act of receiving attention may have acted as a confounding variable. In other words, any additional form of attention may have an impact on the behavioral outcome in question and, thus, it is unknown if the intervention being tested produced the effect.

It is also unclear if these interventions can be used as a form of treatment for behavioral symptoms as opposed to prevention. Many of the interventions were performed during a predetermined time with an observer rating behavior before, during, and after the intervention. Thus, patients may not have been experiencing the behavior in question prior to the intervention. It is possible that the prevention of behavioral symptoms may be easier to address rather than intervening once patients start to experience behavioral symptoms. Further research is needed to determine the impact of non-pharmacological interventions on preventing and treating behavioral symptoms among persons with dementia.

## FUTURE RESEARCH RECOMMENDATIONS

Overall, non-pharmacological treatments for the behavioral symptoms associated with dementia warrant further investigation in the form of large-scale RCTs of adequate duration. Several small studies suggest that some of the interventions (e.g., aromatherapy, music therapy, massage therapy, behavior management techniques, and animal-assisted therapy) may have potential benefits for individuals with dementia. Patients with dementia often have multiple behavioral symptoms associated with their disease (e.g., sleep awakening, aggression, wandering, and depression) that may respond to different interventions. Multi-component studies may be one way to address the multiple needs of patients with dementia.80 Thus, a multi-component strategy to reduce the impact of behavioral symptoms should be included in further research.

Future studies should include RCTs with clearly defined interventions, with a focus on duration and frequency of the intervention as well as adverse effects. Validated tools should be used to measure outcomes; and adequate blinding of participants, raters, and providers is necessary to assure valid, replicable results. The cost-effectiveness, safety, and feasibility of interventions for implementation in VA settings need to be determined.