# CONCLUSIONS

In conclusion, support for psychosocial interventions which effectively treat behavioral symptoms of dementia is mixed at best. For instance, one systematic review found that validation therapy fared better than usual care but produced no significant differences when compared to social contact or reality orientation for general behavioral symptoms. Validation therapy showed increased benefit compared to social contact for depression at 12-month follow-up, but it did no better than usual care or reality orientation. Findings from three additional reviews found no evidence that validation therapy reduces behavioral symptoms of dementia. The results were inconclusive for simulated presence therapy. One systematic review found that reminiscence therapy was better than no treatment for depression but was not significant in reducing behavioral symptoms, and additional reviews found no evidence to support the use of reminiscence therapy. The effectiveness of light therapy was also mixed, with one review suggesting there may be some benefit for agitation, nocturnal restlessness, and sleep disturbance. Aromatherapy shows some promise for reducing agitation but showed no improvement in aggression. Massage therapy fared better than no treatment in reducing agitation and disturbed behavior when compared to baseline but had no significant effect when compared to calming music. There is no available evidence to suggest that acupuncture is an effective treatment for behavioral symptoms, nor is there evidence that TENS reduces sleep disturbance or behavioral symptoms among patients with dementia. It remains unclear if subjective barriers, multisensory stimulation, exercise, therapeutic touch, aromatherapy, or music have an impact on wandering behavior. Agitation may be reduced by sensory interventions (i.e., aromatherapy, thermal bath, calming music, and hand massage); but there is currently no evidence to suggest that social contact, environmental modification, caregiver training, combination therapy, or behavior therapy is effective. There is preliminary evidence to suggest that systematic individualized intervention may be effective in reducing agitation, though this research is limited by methodology and therefore needs to be replicated with adequate blinding procedures to assure valid results. Finally, initial research on behavior management techniques is promising though inconsistent; methodologically rigorous replication studies utilizing adequate blinding procedures and standardized treatments across research labs and patient settings are needed to confirm the preliminary, positive results.

The summary of findings and quality of the evidence for each form of therapy is presented in Table 3. We defined the level of evidence using the definitions of the GRADE working group,81 as follows:

- High – Further research is very unlikely to change our confidence in the estimate of effect;
- Moderate – Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate;
- Low – Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate;
- Very low – Any estimate of effect is very uncertain.

Table 3 Summary of findings

Intervention | Studies included in Systematic Reviews (SRs) | Quality of data: Most recent search date Length of follow-up Consistency of findings | Estimate of benefit; overall level of evidence | Study limitations | Comments on feasibility and acceptability
Emotional Oriented Approaches
Reminiscence Therapy | 7 RCTs | Most recent search date: March 2006 Follow-up: ≥ 4 weeks Consistency of findings: Showed no benefit, except for depression in 1 small RCT | Neutral effect; low | Evidence is based on a small number of studies with very small sample sizes. | Requires a master's level counselor for implementation. Patients and caregivers appear to enjoy the intervention.
Simulated Presence Therapy (SPT) | 1 RCT and 3 other studies | Most recent search date: February 2008 Follow-up: Not reported Consistency of findings: No, studies showed mixed results | Inconclusive; low | Included studies were not quality rated. Variability in outcome measures used and in the administration of SPT. Findings are based on small sample sizes. | Requires a master's level counselor for implementation.
Validation Therapy | 3 RCTs and 2 other studies with small samples (N=5) in each | Most recent search date: March 2006 Follow-up: 6 weeks to 12 months Consistency in findings: No, studies showed mixed results. | Inconclusive; low | Small sample sizes. | Requires a master's level counselor for implementation. Included studies had high levels of intervention intensity.
Stimulation Oriented Approaches
Acupuncture | No studies met inclusion criteria | Most recent search date: February 2007 | Inconclusive; no studies | NA | Requires a certified therapist.
Aromatherapy | 1 RCT and 1 other study | Most recent search date: March 2008 Follow-up: ≤ 4 weeks Consistency of findings: Yes | Positive effect on agitation; low | Findings are based on a small sample. Possible problems with heterogeneity and other confounding variables. | May be easily implemented in a group setting without extensive training.
Light Therapy | 4 RCTs, 4 other studies | Most recent search date: December 2005 Follow-up: No follow-up to 1 week Consistency of findings: No, studies showed mixed results | Positive effects on agitation and sleep; low | Overall findings are based on a small number of poor quality studies with very small sample sizes. | Depends on the method of therapy administered.
Massage and Touch | 3 RCTs | Most recent search date: July 2005 Follow-up: 1 hr post treatment to 5 days Consistency of findings: Yes | Positive effects on agitation; low | Study findings are based on small sample sizes and limited treatment duration. Similar to calming music in preventing agitation. Support for massage compared to no treatment. | Depends on the type of therapy: A licensed massage therapist would be needed for some treatments; hand massage and touch therapy may be easier to implement. The increased stimulus could increase agitation and aggression in some individuals.
Music Therapy | 4 SRs that included 3 RCTs | Study designs: Mostly time series in which subjects served as their own controls; also RCTs and case studies Quality rating: RCTs were poor Data sparseness: Samples were small; the largest study had 39 subjects Consistency of findings: Yes | Positive effects on agitation; low | Limitations: Well-conducted studies are lacking. Benefits appear to be short-term. | Some music interventions are simple and low-cost (e.g., playing recorded music at mealtimes) and may be feasible for wide implementation. The increased stimulus could increase agitation and aggression in some individuals.
Snoezelen Multisensory Therapy | 6 RCTs | Most recent search date: March 2008 Follow-up: ≤ 1 month Consistency of findings: No, studies showed mixed results | Inconclusive; moderate | Variability of intervention components in included studies. | May be easily implemented in a group setting without extensive training.
Transcutaneous Electrical Nerve Stimulation (TENS) | 3 RCTs | Most recent search date: December 2005 Follow-up: ≤ 6 weeks Consistency of findings: Yes (data were pooled) | Neutral effect; low | Individual studies consisted of small sample sizes. | Would most likely require a trained OT or PT or master's level psychologist.
Behavior Management Techniques
Behavior Management Techniques | 7 RCTs plus 2 recent primary studies identified by peer review | Most recent search date within SRs: January 2006 Follow-up: ≤9 months Consistency of findings: No, studies showed mixed results | Mixed results across outcomes; low | Inadequate blinding procedures; control groups primarily usual care rather than alternative interventions. | Varies based on type of intervention; many interventions likely able to be implemented in VA settings, though individualization to patients is often needed. Likely requires master's level therapist or psychologist.
Other Psychosocial Interventions
Animal-assisted Therapy | 9 primary studies, no RCTs | Study design: Uncontrolled time series and non-randomized controlled trials Quality rating: Not applicable to study design Data sparseness: # participants ranged from 6 to 62 per study/length of follow-up ranged from same day of intervention to 4 weeks Consistency of findings: No, studies showed mixed results | Positive effects on agitation, passivity, social interactions, and nutritional intake; very low | Studies were small and heterogeneous, and lacked methodological rigor. | Among the therapies studied, fish aquariums and visiting dog therapy may be feasible for broad implementation in VA.
Exercise | 3 SRs: 18 RCTs and 17 other trials | Most recent search date: September 2007 Follow-up: 5 days to 24 months Consistency in findings: No, studies showed mixed results | Positive effects on sleep; very low overall; moderate for outcome of sleep | Small sample sizes, variation in intervention intensity and duration, variation in baseline dementia severity. Poor methodology. | Varies based on intensity of intervention, but some interventions (e.g., walking) could be accomplished without specialized training.
Targeted Behavioral Symptoms
Wandering | Subjective barriers: No RCTs met inclusion criteria | Most recent search date: March 2009 | NA; no evidence | NA | NA
Wandering | Various sensory stimulation therapies: 8 RCTs, 3 non-RCT parallel and cross-over studies | Most recent search date: October 2005 Follow-up: range 3 days to < 1 year (mean 6 weeks) Consistency of findings: No, studies showed mixed results | Inconclusive; low | Evidence is based on a small number of studies within each intervention category. Quality of studies was poor, with limited methodological reporting. | Music, exercise, and multisensory stimulation appear to be pleasant and enjoyable for patients. The increased stimulation could increase agitation and aggression in some individuals. These interventions are likely easy to implement in VA settings at low cost.
Wandering | GPS tracking devices, boundary alarms, other monitoring devices | Case studies; cross-sectional studies; or single-group, pre- and post-test/post-test only studies. Search date through 2006. | Improved patient safety; very low | Studies were small and lacked a control group. | Costly and resource intensive, requiring training and technical support. Increases caregiver peace of mind.
Agitation | 7 RCTs and 7 randomized cross-over studies, plus 1 recent primary study identified by peer review | Follow-up: Up to 2 months (study grouped follow-up < 2 mos. and > 2 mos.) Consistency of findings: Yes (data were pooled) | Positive effects on agitation with sensory interventions and systematic individualized intervention; low | Small number of studies for each type of therapy; variability in duration of treatment and measuring instruments. | Aromatherapy, thermal bath, calming music, and hand massage are low-cost and have some evidence of benefit.
Inappropriate Sexual Behavior | No SRs found | There is no available evidence to support or refute the effectiveness of non-pharmacological treatments for inappropriate sexual behavioral among patients with dementia. | NA | NA | NA