# ABBREVIATIONS

AA: African American
AARS: Apparent affect rating scale
AAT: Animal-assisted therapy
ABID: Agitated Behaviors in Dementia
AD: Alzheimer's disease
ADL: Activities of daily living
ADRDA: Alzheimer Disease and Related Disorders Association
AGECAT Organic, Depression: AGECAT is a computerised diagnostic system designed for use with the Geriatric Mental State and the History and Aetiology Schedule (designed to collect information about the history of the respondent with special reference to psychiatric illness including dementia, and about putative aetiological factors) for use in research with older people. AGECAT contains syndrome clusters for organic, anxiety, depression, etc.
AHRQ: Agency for Healthcare Research and Quality
AoA: Administration on Aging
BACS: Beliefs about Caregiving Scale
BAI: Beck Anxiety Inventory
BDI: Beck Depression Inventory
BDRS: Blessed Dementia Rating Scale
BEHAVE: Behavioral Pathology in Alzheimer's Disease Rating Scale
BMT: Behavior management training
BPRS: Brief Psychiatric Rating Scale
BRAD: Behavior Rating in AD
BVRT: Benton Visual Retention Test
CAS: Clinical Anxiety Scale
CES-D: Center for Epidemiologic Studies Depression Scale
CF: Category fluency
CG: Caregiver
CHS-M: Modified Caregiver Hassles Scale
CI: Confidence interval
CMAI-O, CMAI-N: Cohen-Mansfield Agitation Inventory - observer-derived score, nursing staff-derived score
COPE: Care of Persons with Dementia in their Environments
COWA: Controlled oral word association
CQLI: Caregiver Quality of Life Instrument
CR: Care recipient
CSDD: Cornell Scale for Depression in Dementia
CSQ: Caregiver sleep questionnaire
CTIS: Computer-Telephone Integration System
DBS: Disruptive behavior scale
DMSS: Dementia Management Strategies Scale
DRS: Depression Rating Scale
DSC: Dementia Steering Committee
ECR: Elderly Caregiver Family Relationship
EPC: Evidence Based Practice Center
ESP: Evidence-based Synthesis Program
FIM: Functional Independence Measure
GDRS: Geriatric Depression Rating Scale
GDS: Global Deterioration Scale
GIPB: Geriatric Indices of Positive Behavior
GPS: Global Positioning System
GQ-SRs: Good quality systematic reviews
HBPC: Home Based Primary Care
HDLF: Health and Daily Living Form
HDRS: Hamilton Depression Rating Scale
HSR&D: Health Services Research and Development
HTA: Health Technology Assessment
IADL: Instrumental Activities of Daily Living scale
ICT: Information and Communication Technology
ITT: Intention-to-treat
LSIZ: Life Satisfaction Index
LSNI: Lubben Social Network Index
LTC: Long-term care
MAACL: Multiple Affect Adjective Checklist
MADDE: Medicare Alzheimer's Disease Demonstration and Evaluation program
MAI: Multilevel Assessment Inventory
MBPC: Memory and Behavior Problems Checklist
MFW: Minnesota Family Workshop
MMSE: Mini Mental State Exam
MOSES: Multidimensional Observation Scale for Older Subjects
MPB: Management of Problem Behaviors
MSS: Multisensory stimulation
N: Number
NHS: National Health Service
NIA/NINR: National Institute on Aging/National Institute of Nursing Research
NICE: National Institute for Health and Clinical Excellence
NINCDS: National Institute of Neurological and Communicative Diseases and Stroke
NPI: Neuropsychiatric Inventory
NYU: New York University
OARS: Older Americans Resource and Services Multidimensional Functional Assessment Questionnaire
ODAS: Observable displays of affect scale
OGEC: Office of Geriatrics and Extended Care
PAC: Positive Aspects of Caregiving scale
PAIS: Psychological Adjustment to Relative's Illness
PAVeD: Preventing Aggressive Behavior in Demented Patients
PCI: Patient Care Index
PDC: Partners in Dementia Care
PHQ9: Patient Health Questionnaire-9 Item
PIC: Partners in Caregiving
POMS: Profile of Moods States
PSS: Perceived Stress Scale
QALY: Quality of adjusted life years
QOL/QoL: Quality of life
RAGE: Rating Scale for Aggressive Behavior in the Elderly
RCT: Randomized controlled trial
REACH: Resources for Enhancing Alzheimer's Caregiver Health
RIL: Record of Independent Living
RMBPC: Revised Memory and Behavior Problem Checklist
RSCSE: Revised Scale for Caregiving Self-Efficacy
SADS: Social Avoidance and Distress Scale
SBP: Stress-Busting Program
SCB: Screen for Caregiver Burden
SCN: Suprachiasmatic nuclei
SF-36 (PF, PRF): Short-form health survey (physical functioning and physical role functioning subscales)
SIP (BCM, M, HM): Sickness Impact Profile (mobility scale; home management subscale
SPT: Simulated presence therapy
SR: Systematic Review
SSCQ: Short Sense of Competence Questionnaire
STAI: State Trait Anxiety Inventory
STAXI: State Trait Anger Expression Inventory
T1: Timepoint 1
T2: Timepoint 2
TENS: Transcutaneous electrical nerve stimulation
TLC: Telephone-Linked Care
Tx: Treatment
UK: United Kingdom
VA: Veterans Affairs
VAMC: Veterans Affairs Medical Center
VAS: Visual analog scale
VHA: Veterans Health Administration
VISN: Veterans Integrated Service Network
VSO: Visit Satisfaction Questionnaire
ZBI: Zarit Burden Interview