# QUALITY RATING CRITERIA FOR SYSTEMATIC REVIEWS^*^ * Created from the following publications: Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001:20(3S); 21-35. National Institute for Health and Clinical Excellence. The Guidelines Manual. London: Institute for Health and Clinical Excellence; 2006. Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991; 44:1271-8.

Overall quality rating for each systematic review is based on the below questions. Ratings are summarized as: Good, Fair, or Poor:

- Search dates reported? Yes or No
- Search methods reported? Yes or No
- Comprehensive search? Yes or No
- Inclusion criteria reported? Yes or No
- Selection bias avoided? Yes or No
- Validity criteria reported? Yes or No
- Validity assessed appropriately? Yes or No
- Methods used to combine studies reported? Yes or No
- Findings combined appropriately? Yes or No
- Conclusions supported by data? Yes or No

## Definitions of ratings based on above criteria

[underlined: Good:] Meet all criteria: Reports comprehensive and reproducible search methods and results; reports pre-defined criteria to select studies, and reports reasons for excluding potentially relevant studies; adequately evaluates quality of included studies and incorporates assessments of quality when synthesizing data; reports methods for synthesizing data and uses appropriate methods to combine data qualitatively or quantitatively; conclusions supported by the evidence reviewed.

[underlined: Fair:] Studies will be graded fair if they fail to meet one or more of the above criteria, but the limitations are not judged as being major.

[underlined: Poor:] Studies will be graded poor if they have a major limitation in one or more of the above criteria.