# SEARCH STRATEGY FOR PRIMARY STUDIES ON ANIMAL-ASSISTED THERAPY FOR DEMENTIA

## PubMed search 12/9/2009, 275 results

“humans”[MeSH Terms] AND ((((((((((pet therapy[tiab] OR animal assisted therapy[tiab]) OR animal therapy[tiab]) OR dog therapy[tiab]) OR dog assisted therapy[tiab]) OR animal-assisted activities[tiab]) OR animal-assisted interventions[tiab]) OR aquarium[tiab]) OR ((“Dogs”[Mesh] OR “Cats”[Mesh]) OR “Birds”[Mesh])) OR (“Bonding, Human-Pet”[Mesh] OR “Animals, Domestic”[Mesh])) AND (“dementia”[MeSH Terms] OR “dementia”[All Fields]))

## PsycINFO search 12/9/2009, 83 results (61 unique)

PsycINFO 1806 to December Week 2 2009

# | Searches | Results
1 | pet therapy.mp. or exp Animal Assisted Therapy/ | 335
2 | animal assisted therapy.mp. or exp Animal Assisted Therapy/ | 330
3 | animal assisted therapy.mp. | 330
4 | exp Interspecies Interaction/ or exp Pets/ or exp Dogs/ | 5351
5 | dog therapy.mp. | 8
6 | dog assisted therapy.mp. | 3
7 | animal assisted activities.mp. | 18
8 | animal assisted interventions.mp. | 10
9 | aquarium.mp. | 269
10 | cats.mp. or exp Cats/ | 11113
11 | birds.mp. or exp Birds/ | 22735
12 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 | 38995
13 | dementia.mp. or exp Dementia/ | 45487
14 | 12 and 13 | 83
15 | from 14 keep 1-10 | 10
16 | from 14 keep 1-83 | 83

## CINAHL search 12/9/2009, 65 results (44 unique)

# | Searches | Results
S14 | S12 and S13 | 65
S13 | (“dementia”) or (MH “Dementia+”) | 23,299
S12 | S1 or S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 | 3,595
S11 | (“birds”) or (MH “Birds”) | 926
S10 | (“cats”) or (MH “Cats”) | 923
S9 | aquarium | 20
S8 | “animal assisted interventions” | 7
S7 | “animal assisted activities” | 4
S6 | (“dog assisted therapy”) or (MH “Service Animals”) | 126
S5 | “dog therapy” | 0
S4 | (“pets”) or (MH “Pets”) | 1,279
S3 | (“human pet bonding”) or (MH “Human-Pet Bonding”) | 288
S2 | “animal assisted therapy” | 105
S1 | (“pet therapy”) or (MH “Pet Therapy”) | 526

Deduplication notes – MPF 10Dec09

Total citations after deduplication = 371