# SEARCH STRATEGY FOR NON-PHARMACOLOGICAL TREATMENT OF DEMENTIA, REVIEWS

MEDLINE (PubMed) searched on 10/08/2009

Search # | Concept | Search String | N
1 | Dementia | “dementia”[MeSH Terms] OR “dementia”[All Fields] OR dement*[tiab] OR “mild cognitive impairment” [tiab] | 110,737
2 | Non-Pharmacological treatments | (“non pharmacologic*”[tiab] OR “non-pharmacologic*”[tiab] OR “nonpharmacologic*”[tiab]) AND (therapy [tiab] OR intervention [tiab]) | 1,357
3 | Psychotherapy | “psychotherapy” [MeSH Terms] OR “psychotherapy” [tiab] | 126,941
4 | exercise/physical activity | “Exercise/therapy” [Mesh] OR “Exercise Therapy” [Mesh] OR “exercise” [tiab] OR “motor activity” [MeSH Terms] OR (“motor” [tiab] AND “activity” [tiab]) OR “motor activity” [tiab] OR (“physical” [tiab] AND “activity”[tiab]) OR “physical activity ”[tiab] | 281,156
5 | transcutaneous electrical nerve stimulation (TENS) | “transcutaneous electrical nerve stimulation” [tiab] OR (“transcutaneous electric nerve stimulation” [MeSH Terms] OR (“transcutaneous” [tiab] AND “electric” [tiab] AND “nerve” [tiab] AND “stimulation” [tiab]) OR “tens” [tiab]) | 9,317
6 | snoezelen multi-sensory stimulation | “Snoezelen” OR “multisensory stimulation” OR “multi sensory stimulation” OR “multi-sensory stimulation” OR “multisensory environment” OR “multi sensory environment” OR “multi-sensory environment” | 108
7 | bright light therapy | “phototherapy” [MeSH Terms] OR “phototherapy” [tiab] OR (“light” [tiab] AND “therapy” [tiab]) OR “light therapy” [tiab] OR “photo-therapy” [tiab] OR “light-therapy” [tiab] | 31,862
8 | smart home technologies | (Home-based[tiab] AND (assistive technologies[tiab] OR assistive technology [tiab])) OR smart home technologies [tiab] OR smart home technology [tiab] OR (“Telemetry” [Mesh] OR “Telemedicine”[Mesh]) | 16,073
9 | acupuncture | “acupuncture” [MeSH Terms] OR “acupuncture” [tiab] OR “acupuncture therapy “[MeSH Terms] | 14,240
10 | massage and touch therapies | (“touch”[MeSH Terms] OR “touch” [tiab]) AND (“therapy”[Subheading] OR “therapy” [tiab] OR “therapeutics” [MeSH Terms] OR “therapeutics” [tiab]) OR “Massage” [Mesh] OR “massage” [tiab] | 13,184
11 | music therapy | “music therapy “[MeSH Terms] OR (“music” [tiab] AND “therapy “[tiab]) OR “music therapy “[tiab] | 1,990
12 | sensory stimulation | “sensory stimulation”[tiab] | 1,514
13 | aromatherapy | “aromatherapy”[MeSH Terms] OR “aromatherapy”[tiab] OR (“aroma” [tiab] AND “therapy” [tiab]) OR “aroma therapy” [tiab] | 590
14 | reality orientation | “Reality Therapy” [Mesh] OR reality orientation [tiab] OR reality therapy [tiab] | 374
15 | behavioral management | (behavior* [tiab] AND management [tiab]) OR Behavior Therapy [MeSH] | 50,249
16 | simulated presence | “simulated presence” [tiab] | 10
17 | reminiscence therapy | (“reminisce” [tiab] OR “reminiscence” [tiab]) AND (“therapy” [tiab] OR “technique*” [tiab] OR “treatment” [tiab] OR “intervention” [tiab] OR “group” [tiab]) | 224
18 | validation therapy | “validation” [tiab] AND (“therapy” [tiab] OR “technique*” [tiab] OR “treatment” [tiab] OR “intervention” [tiab]) | 13,769
19 | all treatments | OR (#2-18) | 506,887
20 | all treatments for dementia | #19 AND #1 | 4,729
21 | non-indexed articles from set #20 | #20 AND (in process [sb] OR publisher[sb] OR pubmednotmedline [sb]) | 140
22 | indexed articles from set #20 | #20 NOT #21 | 4,589
23 | articles indexed as systematic reviews | #22 AND systematic [sb] | 196
24 | (systematic reviews, or un-indexed) English only | (#23 OR #21) AND English[lang] | 304

The symptoms, comparators, outcomes and settings are best dealt with using inclusion and exclusion criteria, including them in the search risks artificially limiting the search results.

PsycINFO (OVID)searched on 10/08/2009

Search # | Concept | Search String | N
1 | Dementia | exp dementia/ or exp alzheimers disease/ or exp cognitive impairment/ or Dementia.mp. | 52,506
2 | Psychotherapy | psychotherapy.mp. or exp Psychotherapy/ | 169,679
3 | exercise/physical activity | exp physical activity/ or exercise.mp. or physical activity.mp. | 30,661
4 | transcutaneous electrical nerve stimulation (TENS) | exp Electrical Stimulation/ or transcutaneous electrical nerve stimulation.mp. or tens.mp. | 14,847
5 | snoezelen multi-sensory stimulation | snoezelen.mp. or perceptual stimulation.mp. or exp Perceptual Stimulation/ or multi sensory stimulation.mp. or multi sensory environment.mp. | 49,928
6 | bright light therapy | light therapy.mp. or exp Phototherapy/ | 801
7 | smart home technologies | (exp Technology/ and exp Housing/) or smart home.mp. or exp telemedicine/ | 1,122
8 | acupuncture | acupuncture.mp. or exp Acupuncture/ | 759
9 | massage and touch therapies | exp Massage/ or massage.mp. or exp Physical Contact/ or touch therapy.mp. | 2,162
10 | music therapy | music therapy.mp. or exp Music Therapy/ | 2,763
11 | aromatherapy | aromatherapy/ or olfactory stimulation/ or (aromatherapy or aroma therapy).mp. | 1,1661
12 | reality orientation | exp Reality Therapy/ or reality orientation.mp. or reality therapy.mp. | 964
13 | behavioral management | exp Behavior Therapy/ or exp Behavior Modification/ or behavioral management.mp. | 34,227
14 | simulated presence | simulated presence.mp. | 12
15 | reminiscence therapy | exp Reminiscence/ or reminiscence therapy.mp. | 1,200
16 | validation therapy | validation therapy.mp. | 39
17 | all treatments | OR (#2-16) | 286,924
18 | all treatments for dementia | #17 AND #1 | 2.150
19 | systematic reviews | limit #18 to (“0800 literature review” or “0830 systematic review” or 1200 meta analysis) | 127
20 | English | limit 19 to english language | 120

After de-duplication with PubMed results : 102 unique citations

Cochrane Database of Systematic Reviews & Cochrane Database of Abstracts of Reviews of Effects (OVID) searched on 10/08/2009

Search # | Concept | Search String | N
1 | Dementia | dementia.mp. or alzheimers.mp. or cognitive impairment.mp. | 559
2 | Non-Pharmacological treatments | non-pharmacological treatment.mp. | 37
3 | Psychotherapy | Psychotherapy.mp. | 587
4 | exercise/physical activity | exercise.mp. or physical activity.mp. | 1,750
5 | transcutaneous electrical nerve stimulation (TENS) | transcutaneous electrical nerve stimulation.mp. or tens.mp. | 181
6 | snoezelen multi-sensory stimulation | snoezelen.mp. or multi sensory environment.mp. or multi-sensory stimulation.mp. | 10
7 | bright light therapy | light therapy.mp. or phototherapy.mp. | 0
8 | smart home technologies | smart home.mp. or telemedicine.mp. | 60
9 | acupuncture | acupuncture.mp. | 1
10 | massage and touch therapies | massage.mp. or touch.mp. | 391
11 | music therapy | music therapy.mp. | 78
12 | sensory stimulation | sensory stimulation.mp. | 23
13 | aromatherapy | (aromatherapy or aroma therapy).mp. | 45
14 | reality orientation | reality orientation.mp. or reality therapy.mp. | 18
15 | behavioral management | behavioral management.mp. or behavior therapy.mp. or behavior modification.mp. | 270
16 | simulated presence | simulated presence.mp. | 6
17 | reminiscence therapy | reminiscence therapy.mp. | 11
18 | validation therapy | validation therapy.mp. | 5
19 | all treatments | OR (#2-18) | 2,848
20 | all treatments for dementia | #19 AND #1 | 158

No duplicated detected by EndNote