# RESULTS

## LITERATURE SEARCH

Figure 1 shows the yield and flow of the literature search. yielded 1,711 citations. After abstract review (see Appendix A), de-duplication of remaining articles retrieved from both databases, and the removal of systematic reviews that had been updated (for example, if there were three Cochrane reviews on a topic, only the most recent update was retained), a total of 112 review articles were retained for full-text review. Of these, we included 15 that met our criteria for good quality systematic reviews (Appendix B). We included one review of respite care and three reviews of technology-based interventions.

Figure 1 Literature Flow

There were 11 systematic reviews that evaluated a variety of psychosocial interventions in 224 primary studies. Of these, we examined 78 primary studies that had been rated good quality in the systematic reviews. Among these 78 studies, we identified 30 RCTs of psychosocial interventions that met our quality criteria for study design and sample size.

We also examined three good-quality studies found in the compendium of intervention studies compiled by the AoA Alzheimer’s Disease Supportive Services Program,2 six studies that were identified by peer reviewers, and one good quality RCT published just as we were concluding our response to peer review.

## KEY QUESTION #1. Do CG interventions affect the CG’s knowledge and ability to manage problematic behavior, psychosocial burden, health and health behaviors, or outcomes in the individual with dementia?

### PSYCHOSOCIAL INTERVENTIONS

The results on psychosocial interventions are organized in the following subcategories: multicomponent studies; exercise training; case management; behavior management training (BMT); individual skills training; group skills training and combined individual/group skills training; and individual, group, and combined individual/group supportive counseling.

#### MULTICOMPONENT STUDIES

Summary impact of multicomponent interventions: There is no consistent evidence that multicomponent interventions delayed CR institutionalization. Individually tailored intensive, multicomponent interventions show promise for reducing CG depression, and in improving sense of burden, self care abilities, well-being, confidence, and social support ratings. When examined across diverse populations, there were group effects for all Latino/Hispanic and White/Caucasian CGs, as well as Black/African-American spousal CGs. Additionally, CGs who experience individually crafted interventions during their caregiving period may fare better during the bereavement phase.

Five studies evaluated a combination of varied treatment approaches such as skills training, group support, and respite care (Table 1). In one study, two treatment groups were compared to a respite control condition.6 CGs in Treatment 1 received 10 days of structured group support and skills training to improve coping, set limits, seek support, reduce guilt, and reframe challenges while living in a residential setting (as non-admissions in a psychiatric ward of a general teaching hospital) while CRs participated in separate structured training for memory enhancement. Follow-up phone calls and trainings continued for 12 months. Treatment 2 consisted of a six-month wait list, then entry into similar treatment and follow-up for 12 months. Both groups were compared to a control condition in which the CG received 10 days respite with phone follow-up similar to Treatment 1. All CRs across the three conditions received 10-day memory activity training. CRs of CGs who received training (Treatments 1 & 2 combined) had significantly delayed institutionalization compared to respite control, with effects evident across eight years in survival analysis. No other outcomes were reported. The three groups were comparable for average age of CGs and CRs, CR performance on the Mini Mental Status Examination,7 average CR performance on the Clinical Dementia Rating Scale,8 and rates of decline on measures of instrumental ADL and ADL at 3, 6, and 12 months after training.

Table 1 RCTs of multicomponent interventions for caregivers of individuals with dementia

Study | Brodaty, et al. 1997^6^ | Drummond, et al. 1991^9^ | Belle, et al. 2006 10 REACH II | Holland, et al. 2009 11 | Gitlin, et al. 2010 12
Population (N) | Individuals with dementia and their coresident CG. (N=96, with 93 completing) | CG living with a cognitively impaired relative judged unlikely to be institutionalized during study. (N=60) | Individuals with AD or related disorders and their caregivers who reported distress associated with caregiving, grouped by caregiver ethnicity. (Hispanic/Latino N = 212, White/Caucasian N = 219, Black/African-American N = 211). (642) | Bereaved family caregivers of decedent individuals who had Alzheimer’s dementia. (N = 224, subset of REACH study) | Individuals with dementia and their family CGs who reported difficulty managing CR functional decline or behaviors. (N=209)
Intervention (N) | All CRs received 10-day training on memory tips and activities. Treatment 1) CG received 10-day structured residential training to improve coping, set limits, seek support, reduce guilt, and reframe challenges, with follow-up phone calls and trainings for 12 mos. (N=33) Treatment 2) Wait list, entered into treatment 1 after waiting 6 months, similar follow-up for 6 mos. (N=31) | Weekly in-home respite care (4 hours), weekly nurse home visits to provide education and training, and monthly self-help support group for 6 months. (N=30) | Six month program of 12 in-home and telephone individually tailored active interventions including skills training, problem solving, stress management training, and didactics, with 5 structured phone support group sessions. Written resource materials supplemented training. (N =323; 106, 113, 104, respectively by ethnicity) | Active interventions varied across REACH sites, often multicomponent, included behavioral interventions, environmental modifications, support directly and/or by phone and/or computer | Tailored assessment, CG education, CG training. 102 dyads received up to 10 sessions with an occupational therapist over 4 months, and 1 face-to-face session and 1 phone session with an advance practice nurse.
Control (N) | CG received 10 days respite with similar follow-up to Tx1. (N=30) | Usual care community nursing focused on the CR rather than CG, monitoring medicines and helping with ADL/IADLs. (N=30) | Mailed educational packet, 2 brief phone contacts, plus invitation to join dementia/caregiving work-shop at the end of the study (N = 319; 106, 106, 107 respectively) | Varied across sites, included minimal support and usual care conditions. | Controlled for professional attention and tailoring of information. 107 dyads received up to 3 20-minute phone calls from research staff (not occupational therapists or nurses), and general information brochures.
CG outcome measures | Not evaluated | CQLI CES-D STAI | CES-D, Zarit Caregiver Burden Interview, 11-item health self-care questions 10 items social support measure | Inventory of Complicated Grief Texas Revised Inventory of Grief CES=D | Well-being: 13-item perceived change index (ability to manage dementia, emotional status, somatic symptoms); Confidence: 5-item activities in last month; Satisfaction, perceived benefits.
CG results | Not evaluated. | No significant differences in depression, anxiety, or quality of life. | Significantly greater (statistical) improvements among Hispanic/Latino and White/Cauc participants for depression, burden, self-care, social support, but not for Black/AA participants. Black/AA spouses showed significantly greater improvement than spouses in control group (but not nonspouses). Net clinical improvement across 5 domains greater in intervention than control group for Hispanic/Latino participants. White participants showed clinically meaningful effect with social support. Black/AA participants showed clinically meaningful differences for burden and self care, for spouses only. Overall prevalence of depression higher for controls at follow-up. | CGs in intervention groups reported significantly fewer normal grief symptoms than control condition. Nonsignificant trend for reduced complicated grief in intervention group. No effects seen for depression Cognitive-behavioral interventions seem to be most effective as preventative for complicated grief. | Adjusted mean difference (95% CI) at 4 months: Improved well-being, PCI: 0.22 (0.08–0.36) Confidence using activities: 0.81 (0.30–1.32) More COPE CGs reported eliminating at least 1 problem: 62.7% vs. 44.9% (p=0.01).
CR outcome measures | ADL IADL Months to nursing home admission Months to death | Not evaluated. | 3 items from RMBPC Institutionalization at 6-mo. follow-up | --- | FIM; 12-item QOL-AD; 16-item Agitated Behavior in Dementia Scale; Activity Engagement
CR results | CR of groups who received training (Tx 1 & 2 combined) had significantly delayed institutionalization compared to respite control. Survival analysis over 8 years indicates training resulted in CR remaining in home longer. | Not evaluated. | Significantly greater improvements among Hispanic/Latino and White/Cauc participants for CR problem behaviors, but not for Black/AA. Clinically significant improvements in problem behavior score for Latino/Hispanic. No differences in institutionalization at follow-up. | --- | Adjusted mean difference (95%CI) at 4 months: Improvements in functional dependence: 0.24 (0.03–0.44); Improved engagement: 0.12 (0.07–0.22).
Comments | Residential program serving 4 CR-CG dyads at a time in small groups. Setting could be hotel or other grouping. | Economic analysis determined that the annual incremental cost of providing the support program was $2,204 (Canadian dollars) per caregiver, and that the improvement in CG QoL (as measured by the CQLI) was 0.11 over the 6-month intervention period. The implied incremental cost per QALY gained is therefore $2,204/0.11 or $20,036. | Stratified randomized assignment by site, ethnicity, and dyadic relationship. Follow-up limited to 6 mos., no 12 mo. data. According to authors: treatment is feasible in community settings delivered by BA in psychology, social work, nursing, OT or related. | Noncompleters similar to completers on care demographics. Universal, rather than targeted interventions, likely to show smaller effect sizes. | A high prevalence (close to 40%) was found of undiagnosed, treatable medical conditions among intervention CRs.

Abbreviations: AA = African American; ADL = activities of daily living; CES-D = Center for Epidemiologic Studies Depression Scale; CG = caregiver; CQLI = Caregiver Quality of Life Instrument; CR = care recipient; GQ-SR = good-quality systematic review; IADL = Instrumental Activities of Daily Living scale; ITT = intention-to-treat; PCI = patient care index; QALY = quality of adjusted life years; STAI = State Trait Anxiety Disorder; Tx 1 = treatment 1; Tx 2 = treatment 2.

The second study provided weekly in-home respite care (four hours) plus weekly home visits by a nurse to provide CG education and training, and monthly self-help CG support groups for six months.9 This intervention was compared to usual care control offering community nursing focused on the CR rather than CG, with monitoring of medicines and help with activities of living. While the intervention was associated with a favorable cost per quality-adjusted life year gained, no significant differences in CG or CR depression, anxiety, quality of life, or time to institutionalization were reported.

We considered two studies completed after the previous systematic reviews were published, on the recommendation of our expert panel. An RCT compared a six-month individually tailored program of 12 in-home and telephone interventions (including skills training, problem solving, stress management training, and five structured phone support group sessions with supplemental written resource materials) with control participants who received written informational materials plus an invitation to join a group at the end of data collection (N =642).10 This study also examined the impact of the intervention for different ethnicities, including Hispanic/Latino (N = 212), Black/African-American (N = 211), and White/Caucasian (N = 219). The overall prevalence of CG depression was higher in the control group at follow-up. Hispanic and White participants endorsed significant improvements for depression, burden, self-care, and social support (referred to collectively as “quality of life”), but in the Black group, these findings were supported for spousal CGs only. Clinical improvement (defined as change equal to or greater than 0.5 Standard Deviation) across all measured domains was greater for the CG intervention group than the control group for Hispanic/Latino participants. White CG participants demonstrated clinically meaningful improvements in social support. Black CG participants showed clinically meaningful differences for burden and self care, for spouses only. White and Hispanic CRs had significantly greater improvements in problem behaviors following treatment when compared to control members, but this change did not occur among Black CRs. The intervention had no effect on institutionalization at follow-up.

The second of these recent studies comprised a subset (N = 224) of the REACH program of research, reporting the impact of various REACH interventions and their paired controls across the country on postmortem grief experiences of dementia CGs.11 Overall, CGs who participated in the intervention groups prior to the death of their CR endorsed less normal grief than in the control conditions. There was a nonsignificant trend for reduced complicated grief in the intervention group. No group treatment effects were seen for CG depression. The authors observed across REACH sites that cognitive-behavioral interventions appeared most effective in preventing complicated grief.

A fifth good quality RCT12 was released for publication during our response to peer review. Originating with the Care of Persons with Dementia in their Environments (COPE) trial, this study conducted individual home assessment (N = 102) of CR up to 12 home or telephone visits over four months providing: CG education about their partner’s capabilities, medications, and symptoms; and CG training to address problem behaviors, improve communication, simplify tasks, and reduce environmental stressors, compared to a control group (N = 107) receiving three phone calls and educational materials. Intervention participants demonstrated better outcomes than the control group for CR instrumental ADL and overall functional dependence, CR activity engagement, and CG wellbeing and reported confidence. These effects were still apparent at nine-month follow-up for CGs, but not for CRs.

Limitations of the literature: In the initial studies reviewed, group sizes were small, ranging from 30–33 across both studies, possibly limiting power to detect change. One study found a treatment effect on time to CR institutionalization, but it is difficult to ascertain which aspect(s) of the multicomponent treatment were effective in these studies.

#### EXERCISE TRAINING

Summary impact of exercise training interventions: There is insufficient evidence evaluating the impact of exercise for the CG on CG burden. More studies are needed.

One study, cited by two reviews, evaluated exercise training among 100 sedentary female CGs of a relative with dementia.13 In this study, 51 CGs participated in a home-based exercise training program with 15 supportive telephone contacts, while 49 CGs received an attention-control condition in which CGs received supportive phone calls with nutrition guidance. The exercise training program successfully cultivated adherence to regular exercise participation, with a goal of four 30+ minute sessions per week, but demonstrated no effect on CG depression, stress, anxiety, or burden, compared with the controls. Both exercise and control groups demonstrated decreased depression, stress, and burden, but there were no significant differences between groups. The study authors noted that CGs who were more depressed at baseline demonstrated poorer adherence to the exercise regimen.13

#### CASE MANAGEMENT

Summary impact of case management interventions: Two RCTs published in 2006,^14, 15^ which featured individualized assessment and care plans, report promising improvements in CG depression, stress, and confidence in caregiving, and reductions in CR problem behaviors. Prior to these studies there was little evidence to support that intensive nursing case management has a sustained impact on CG mood or strain. There may be some transience in the timing of beneficial effects, which were evident at some follow-up evaluations and not at others. There is insufficient evidence to support that case management interventions have an impact on rates of CR institutionalization.

Five studies investigated the impact of intensive nurse care case management on CG and CR outcomes, with mixed conclusions (Table 2). Three studies focused on institutionalization outcomes. Eloniemi-Sulkava and colleagues reported lower rates of institutionalization for the first months of the two year program among 53 individuals with dementia whose CGs received telephone and in-home support and psychoeducation, compared to usual care (N=47).16 However, by the end of the two years there were no differences in rates of institutionalization between the intervention and control groups. The authors concluded that severely demented individuals on the verge of institutionalization would most benefit from this kind of program by delaying nursing home placement. Another study reported no evidence that nursing case management delayed institutionalization of the CR when compared to usual care.17 An additional study apparently linked to the Miller, et al., database18 reported there was no reduction in CG strain, burden, or depression resulting from nursing case management intervention that included respite care, home care, and consultation, but did find that the intervention group was more likely to use community services than the control group.

Table 2 RCTs of case management for caregivers of individuals with dementia

Study | Eloniemi-Sulkava, et al. 2001^16^ | Miller, et al. 1999^17^ MADDE study | Newcomer, et al. 1999^18^ | Callahan, et al. 2006^14^ | Vickrey, et al. 2006^15^
Population (N) | Community-living individuals with dementia and their unpaid family CGs. (N=100 dyads) | Community-dwelling CG-care recipient (CR) dyads where CR had dementia and CG was unpaid. (N=8095) | As in Miller, 1999. | Older adults with AD and their CGs. (N=153) | Informal CG-CR dyads from 18 primary care clinics. (N=408)
Intervention (N) | 2-year nurse case management with support, education and cognitive training through telephone and in-home visits facilitated physician referrals, and 24-hour phone availability. (N=53) | Intensive case management, consultation, phone and in-home visits. Program also included respite care, home care, CR occupational therapy, CR nursing care, and case management. (N=4151) | As in Miller, 1999. | Collaborative care management including problem solving, behavior management training, communication skills training, coping skills training, advice, exercise guidelines, information on dementia, and invitation to voluntary support group sessions (attended at least once by 56%). (N=84) | Individualized care manager-led disease management intervention (teaching problem-solving skills, initiating care plan actions and generating a problem list for clinical care) following structured home assessment. Ongoing telephone follow-up with reassessment every 6 mos. (N=238)
Control (N) | Usual care. (N=47) | Usual care. (N=3944) | As in Miller, 1999. | Augmented usual care following any evaluation or treatment deemed appropriate by primary care provider. (N=69) | Usual care. (N=170)
CG outcome measures | Not evaluated. | Not evaluated. Zarit Burden Scale, Geriatric Depression Scale, and Zarit Stress Scale were measured as baseline covariates only. | Zarit Burden Scale Geriatric Depression Scale | NPI CG portion PHQ-9 | CG knowledge of dementia (5 items) CG health
CG results | Not evaluated. | Not evaluated. | CM did not reduce strain or depression for CG. | Significant Intervention group improvements in CG stress at 12 mos. but not 18 mos. on NPI. Improved mood on PHQ9 at 18 months compared to usual care control (but not at 6 or 12 mos.). | Higher confidence in caregiving at 12 and 18 mos. Higher mastery of caregiving skills rated at 18 mos. Higher social support for Intervention group at 18 mos. Health related quality of life equivalent across groups.
CR outcome measures | Rate of institutionalization. | Rate of institutionalization. | Not evaluated. | NPI ADLs Health Care resource use CSDD Telephone Interview for Cognitive Status Medication List | Adherence to 23 guideline recommendations. Use of community resources. CR health CR quality of care
CR results | In early months of study, rate of CR institutionalization was lower in the intervention group. This effect was erased by the 24-month follow-up. | No significant differences in rate of institutionalization overall. Treatment was associated with increased rate of institutionalization (hazard rate 1.21, p=0.043) at 1 of 8 study sites. | Not evaluated. | Significant improvements in total NPI (fewer behavioral symptoms), No impact on CR depression, cognition, or function (ADLs). No influence of intervention on NH placement. | Intervention group had nearly doubled adherence to guidelines. Smaller decline in health-related quality of life for Intervention participants. CR Health care quality rated higher by CGs at 12 and 18 mos.
Comments | Population is Finnish, age 65+, living at home. | Study authors suggest that case managers at one site may have had a “stronger propensity to recommend nursing home placement than in the other sites,” but reasons for why practices would differ were unclear. | Use of community services increased 50% with case management, compared to 40% increase in control participants. | --- | Social workers were usually the care managers, feasibility enhanced by linking dyads to existing community resources rather than duplicating across systems.

Abbreviations: AA = African American; ADL = activities of daily living; CES-D = Center for Epidemiologic Studies Depression Scale; CG = caregiver; CQLI = Caregiver Quality of Life Instrument; CR = care recipient; GQ-SR = good-quality systematic review; IADL = Instrumental Activities of Daily Living scale; ITT = intention-to-treat; PCI = patient care index; QALY = quality of adjusted life years; STAI = State Trait Anxiety Disorder; Tx 1 = treatment 1; Tx 2 = treatment 2.

A fourth study provided collaborative care management for 84 CG-CR dyads with CG training in problem solving, behavior management, communication skills, and coping, as well as provision of advice, exercise guidelines, information on dementia, and invitation to voluntary support group sessions, compared to augmented usual care for 69 dyads, where primary care providers were permitted to refer for any treatments or services deemed appropriate.14 Improvements related to intervention were intermittent but measurable; the authors reported significant intervention group improvements in CG stress as measured by the Neuropsychiatric Inventory for CGs, at 12 months follow-up but not 18 months. CGs under case management also endorsed improved mood on at 18 months compared to usual care control (but not at 6 or 12 months). CRs who participated in the intervention were rated with fewer total behavioral symptoms of dementia at the end of the study, but there was no impact on CR mood, cognition, or ability to complete ADL. The intervention did not influence likelihood of nursing home placement by the end of the study.

A fifth study included 408 CG-CR dyads, and demonstrated beneficial effects of individualized care management that provided teaching problem-solving skills, initiating care plan actions and generating a problem list for clinical care based on in-home structured assessment, compared to usual care.15 Intervention CGs endorsed higher confidence in caregiving at 12 and 18 months, while mastery of caregiving skills and social support were rated as significantly improved over control at 18 months follow-up. CG health-related quality of life did not change as a result of the intervention. For CRs in the intervention group, there was nearly double the adherence to dementia treatment guidelines adopted a priori in the study protocol, and while health-related quality of life dropped for both groups, there was significantly less decline for the intervention participants. CGs also rated higher quality of health care for their CRs in the intervention group.

Limitations of the literature: The reduction in institutionalization in a population of community-dwelling elders in Finland 16 may not readily generalize to US or Veteran populations.

#### BEHAVIOR MANAGEMENT TRAINING (BMT)

Summary impact of behavior management training interventions: A limited body of evidence suggests that BMT may improve CG depression, although this finding was not consistent. Studies where BMT was augmented by CR exercise or CG self-care instruction seemed to result in broader outcome effects, improving CR physical mobility and CG coping skills.

Studies represented in this section specified the use of BMT, which involves identification of probable triggers and consequences of CR behavior disturbance and devising strategies to reduce the frequency of problem behaviors in the CR. Two of four studies provided BMT training to CGs with mixed results (Table 3). One study (N=95) comparing routine medical care with eight weekly in-home BMT sessions/four monthly telephone follow-up calls demonstrated improvements in CG subjective reports of depression and burden, as well as lowered reactivity to CR behavior disturbance and improved CR quality of life. This study also demonstrated that BMT is feasible in the primary care setting.19 Another study (N=62) comparing four group trainings in behavioral interventions over eight weeks to an equivalent number of group sessions providing care-related discussions and advice found no treatment effects between groups, but reported significant pre to post improvement in CR aggression scores within the treatment group.20

Table 3 RCTs of behavioral management training for caregivers of individuals with dementia

Study | Teri, et al. 2005^19^ | Teri, et al. 2003^21^ | Gormley, et al. 2001^20^ | Burns, et al. 2003^22^
Population (N) | 95 family CGs of patients with AD. | 153 CG living with CR who met NINCDS/ADRDA criteria for AD, randomly assigned to intervention or control. | 62 individuals with dementia living with their CG. | 167 dyads of individuals with dementia and their CG randomized to Behavior Care or Enhanced Care. After 24 months, 76 pairs remained active, 30 bereaved, 14 placed in long-term care, and 47 lost to follow-up.
Specific intervention (N) | In-home BMT training for CG in 8 weekly sessions, and 4 monthly follow-up calls. | Combined exercise and CG in-home training in behavior management program “Reducing Disability in Alzheimer Disease” for 3 months. (N=76) | 4 group sessions over 8 weeks teaching behavioral interventions to CG including acting at level of precipitating and maintaining factors, using appropriate communication, accepting false statements by CR (not arguing), and using distraction techniques. Additional problem-solving for unsuccessful interventions. (N=34) | Enhanced Care provided same Behavior Care as control but with 12 additional pamphlets focused on improving well-being of CG, presented during primary care visits by masters-level health educator. Sessions no longer than 60 minutes, with 10-minute phone contacts between sessions. (N =39)
Control (N) | Routine medical care with no specific BMT. | Routine medical care. (N=77) | Equivalent number of group sessions consisting of care-related discussions and advice about available services. (N=28) | Behavior Care provided 25 pamphlets focused on improving BMT repertoire of CG, presented during primary care visits by masters-level health educator. Sessions no longer than 30 minutes, with 10-minute phone contacts between sessions. (N=37)
CG outcome measures | CES-D HDRS Caregiver Sleep Questionnaire Perceived Stress Scale Screen for Caregiver Burden SSCQ | Not evaluated. | ZBI | General Well-Being Scale CES-D RMBPC
CG results | Significantly greater improvements in depression, burden, and reactivity to CR behavior problems at 2 and 6-month post-tests for intervention group; improvements in sleep quality at 6-month follow-up for intervention group. | Not evaluated. | No significant differences between groups in ZBI score post-intervention. | Enhanced Care group showed less bother (RMBPC) at baseline. Lower income and less education at baseline for Enhanced Care participants were controlled in subsequent analyses. General well-being improved significantly for Enhanced Care group over 2 years relative to Behavior Care group; but both groups improved. No significant group benefits over time for depression or risk of depression, though trends suggest possible benefit of Enhanced Care for mood over time.
CR outcome measures | NPI RMBPC QOL-AD | Physical mobility, depression, and institutionalization (MMSE, SF-36, SIP mobility, HDRS, CSDD, RMB-PC, adverse symptom checklist) | BEHAVE-AD RAGE MMSE BDRS | Katz ADL scale, Lawton and Brody IADL scale, and MMSE were collected as part of the larger REACH battery.
CR results | Improved CG ratings of CR quality of life for intervention group at 2-month follow-up; similar trend at 6 months that was significant when controlled for differences in ethnicity. | Compared to routine care, significantly improved scores for physical functioning in intervention group at 3-month and 2-year follow-up, and significantly improved depression (based on direct rater observation and CG interviews) at 3 months. Less institutionalization due to behavior disturbance at 2 years for intervention group, statistically not significant. Higher baseline depression scores predicted significant improvement of intervention over control group at 3-month and 2-year follow-ups. | Baseline RAGE scores were modestly higher in the intervention group with no significant group differences in post treatment aggression scores. Within the intervention group, there was significant reduction in RAGE score from pre to post, but not within the control group. No significant changes in psychotropic prescribing for either group. | Not reported.
Comments | Copy of treatment manual available from Dr. Teri. Somewhat resource-intensive training and supervision of behavior consultants, but could be implemented by VA staff psychologists and social workers. | Results can only be generalized as combined effect, as relative contributions of BMT and exercise were not evaluated. | Difference reported within group, but this analysis loses benefit of randomization. Comparison between randomized groups yielded no significant differences. Evidence from this study is not strong. | No ITT analysis, but shorter length of time performing CG duties was only difference between completers and noncompleters. Blinding not part of protocol.

Abbreviations: AD = Alzheimer’s disease; ADL = activities of daily living; ADRDA = Alzheimer Disease and Related Disorders Association; BDRS = Blessed Dementia Rating Scale; BEHAVE-AD = Behavioral Pathology in Alzheimer’s Disease rating scale; CES-D = Center for Epidemiologic Studies Depression Scale; CG = caregiver; CR = care recipient; CSDD = Cornell Scale for Depression and Dementia; GQ-SR = good-quality systematic review; HDRS = Hamilton Depression Rating Scale; IADL = Instrumental Activities of Daily Living scale; ITT = intention-to-treat; MMSE = Mini Mental State Exam; NINCDS = National Institute of Neurological and Communicative Diseases and Stroke; NPI = Neuropsychiatric Inventory; QOL-AD = Quality of Life in Alzheimer’s Disease; RMBPC = Revised Memory and Behavior Problem Checklist; SF-36 = Short-form health survey; SIP = Sickness Impact Profile; SSCQ = Short Sense of Competence Questionnaire; ZBI = Zarit Burden Interview.

A third study (N=153) offered a combined program of exercise for the person with dementia while supplying BMT for the CG, and reported improved physical health, increased activity, and decreased depression for the CR, as well as a trend toward lower institutionalization rates, compared to usual-care controls.21 No outcomes were measured or reported for the CGs in this study. This combined approach may yield positive outcomes for both members of the dyad. However, it is not possible to separately evaluate the efficacy of the treatment components, as the intervention group combined both BMT for the CG and exercise for the CR.21

One study educated 37 CGs on behavior management techniques through instructive pamphlets and compared that basic intervention with an enhanced intervention (N=39) that added pamphlets on CG self-care.22 CGs in the enhanced care group demonstrated significantly higher ratings of general well-being after two years of intervention, but found no effects on CG mood.

In addition to the RCTs identified from previous systematic reviews, we included three good quality studies23–25 found in the AoA compendium.2 One study demonstrated the applicability of BMT interventions with Chinese-American CGs (N=55), resulting in less bother and lower depression for the treatment group but no difference in overall reported stress.23 Another study (N = 80) reported significantly lower CG distress about CR neuropsychiatric symptoms, but no change in burden for either treatment or control group.24 The third study of 143 CGs reported that the CG treatment group had reduced emotional distress over CR agitated behaviors over time (compared to baseline), but there was no overall group effect for treatment on distress scores.25 The findings of these three studies are relatively consistent with those reported in previous studies.

Limitations of the literature: There was an overall lack of methodologic rigor, and only one study stipulated statistical considerations such as the power to detect a treatment difference or intention-to-treat analysis.19, 21 Heterogeneity in the interventions delivered makes it difficult to combine findings across studies.

#### INDIVIDUAL SKILLS TRAINING

Summary impact of individual skills training interventions: Most studies found no impact on CG’s sense of burden, anxiety, or quality of life, though two of six studies demonstrated that individual skills training for the CG ameliorates depression in CGs. CRs may benefit with slower declines in self-care when skills training includes a component targeting their ADL, and improved mood when pleasant events are scheduled, but these findings were not replicated in other studies. Two of six studies reported that disruptive behavior may be reduced when CGs receive structured training in identifying triggers of disruptive behavior and modifying the environment to reduce stress. There is no consistent evidence documenting impact of skills training programs on delaying or preventing institutionalization of the CR.

Six studies where CGs were taught new skills during individual interactions between the CG and study staff are described here. These interventions typically focused on combinations of: increasing the CG’s repertoire of problem solving strategies, modifying the environment to decrease hazard and reduce triggers of problem behaviors, and/or increasing CG’s sense of support and self-efficacy (Table 4a).

Table 4a RCTs of individual skills training for caregivers of individuals with dementia

Study | Teri et, al. 1997^30^ | Gitlin, et al. 2001^29^ | Buckwalter, et al. 1999^26^ | Gerdner, et al. 2002^28^ | Wright, et al. 2001^31^ | Bass, et al. 2003^27^
Population (N) | Individuals with dementia and their co-resident community CGs. 88 pairs began the study, 72 (82%) completed. | Dementia patients with ADL dependence in 2 areas, difficult behavior and their family CGs. (N=171) | Informal CGs of community-dwelling individual with dementia or memory impairment. (N=245 completed study, missing data for 5, attrition of 28%) | Home CGs of individuals with Alzheimer’s disease. (N=241 yielding 237 complete records) | Family CGs of individuals with dementia previously treated for agitation. (N=93) | Primary family CGs of Kaiser patients who had dementia or memory loss coded in medical record. (N=182 completed first interview, 157 of those also completed 12-month follow-up interview)
Intervention (N) | Two active behavioral treatments involving CG skills training: increasing patient pleasant events (nine 60-minute weekly sessions, N = 23) and CG problem solving strategies without pleasant events focus. (N = 19) | Five home visits by occupational therapists providing CG skills training (environmental modifications, avoiding overstimulation, etc.) and CR ADL training. (N=93) | Progressively Lowered Stress Threshold model of care, individually tailored to problems in the home. Provided 3–4 hours of in-home training and bi-weekly follow-up phone calls for 6 months. (N=132) | Same as control plus individualized care plan presented at 2 in-home visits, 2 weeks apart, building structured routine for CR and modification of environmental challenges (reduce water temperature to prevent scalding, remove mirrors to reduce visual confusion). (N=132) | Individual supportive counseling and strategies for behavior management by nurse after baseline assessment during inpatient admission for 3 home visits (2, 6, and 12 weeks), then 2 phone follow-ups at 6 and 12 months post discharge. (N=68) | Telephone care consultation intervention by Alzheimer’s Association staff. Individual care plan outlines tasks and timelines. Biweekly follow-ups decreasing to 1 and 3-month intervals, adjusted as needed. (60% of sample; N not reported.)
Control (N) | Equal duration typical care, unstructured information, and support for solving patient problems (N = 10), and wait-list control receiving no contact during the 9 week period. (N = 20) | No intervention, provided education materials and a safety booklet at the end of the study. (N=78) | Two in-home visits providing general information about dementia, referral to community-based services and groups, and reading material about dementia. Similar phone follow-up. (N=108) | Receipt of routine information and referrals for community-based services, case management and support groups, provided at 2 one-hour visits, 2 weeks apart. (N=105) | Contact by phone for data collection only, same time points as intervention group. (N=25) | Usual managed care services. (40% of sample; N not reported.)
CG outcome measures | SADS Hamilton DRS was derived from SADS score ZBI | Measured CG ratings of self efficacy and upset in managing dementia behavior. | POMS GDRS | Caregiver response to behavior problems. | Caregiver Hassle Scale CES-D MAI | T1 and T2 interviews: A 2-item index of satisfaction with the types of Kaiser services; an 8-item index of satisfaction with the quality of Kaiser services; a 5-item index of satisfaction with information received about the illness; CG depression measure similar to CES-D.
CG results | CG depression decreased significantly in both treatment groups compared with control conditions. CG results were similar between the 2 active treatment conditions (pleasant events vs. problem solving). | Reduced upset. Women reported increased self-efficacy in managing behaviors, and women and minors reported enhanced self-efficacy in managing functional dependency. | Significantly less depression in intervention group at 6 months, but not at 12-month follow-up. Anger-hostility, fatigue-inertia, confusion-bewil-derment, all significantly lower for intervention group than control at both 6 and 12-month follow- up. | CGs in intervention group had less aversive response to memory/behavioral problems than control participants. Spouses’ response to activities of daily living problems improved with intervention condition. | No effect was demonstrated. | Significantly less CG depression (11 items from CES-D) in intervention vs. control. CGs in intervention group whose CR had not received specific dementia diagnosis rated higher levels of satisfaction with service quality, types of services, and information about the illness.
CR outcome measures | HDRS CSDD BDI MMSE DRS RIL | MBPC FIM | Not evaluated. | MBPC | BDRS CMAI | During a 1-year period: number of hospital admissions, emergency department visits, physician visits, and Kaiser case management visits
CR results | CR depression significantly responded to the 2 treatment conditions compared with the control conditions. CR results were similar between the two active treatment conditions (pleasant events vs. problem solving). | Fewer declines in IADLs and self-care, and fewer behavior problems in intervention group compared with controls at 3-month post-test. | Not evaluated. | Effect of intervention on frequency of behavioral disturbance significant for non-spouse (younger) CGs only. | More CRs remained at home at 12-month follow-up in the intervention group (61% vs. 56% of control CRs), but proportionally fewer deaths in the treatment group (11% vs. 22%) may have contributed to this effect. The proportion institutionalized did not significantly differ between groups (28% Tx vs. 22% controls). | Less use of Kaiser case management and direct care community services with intervention. Less use of non-Alzheimer’s Association information and support services for patients with more severe memory problems with intervention. No differences in use of emergency department, hospital admissions and physician visits.
Comments | No significant differences between baseline measures of completers and noncompleters. | ITT analysis; baseline recorded blind before group assignment. | CGs who were more depressed were more likely to drop out between 6 and 12 months, and institutionalization of their CR more likely. High attrition (28%) but no differential loss to follow-up. | Very high attrition (54%); similar in treatment groups and across research sites. The beneficial effect of the intervention on negative CG reactions was greater among spousal compared with non-spousal CGs. | Large difference in group sizes may have contributed to Type II error. | Physicians and managed care providers blinded to group assignment. Population drawn from primary care and not limited to those seeking help with dementia-related problems.

Abbreviations: ADL = activities of daily living; BDI = Beck Depression Inventory; BDRS = Blessed Dementia Rating Scale; CES-D = Center for Epidemiologic Studies Depression Scale; CG = caregiver; CMAI = Cohen-Mansfield Agitation Inventory; CR = care recipient; CSDD = Cornell Scale for Depression and Dementia; DRS = Dementia Rating Scale; FIM = Functional Independence Measure; GDRS = Geriatric Depression Rating Scale; HDRS = Hamilton Depression Rating Scale; IADL = Instrumental Activities of Daily Living scale; MAI = Multilevel Assessment Inventory; MBPC = Memory and Behavior Problems Checklist; MMSE = Mini Mental State Exam; POMS = Profile of Moods States; RIL = Record of Independent Living; SADS = Social Avoidance and Distress Scale; SR = systematic review; T1 = timepoint 1; T2 = timepoint 2; ZBI = Zarit Burden Interview.

Columns separated by a dashed line indicate that the two publications appear to be related and may be based on the same study

The studies on individual skills training allowed for examination of specific CG outcomes across studies, such as depression, mood, and other CG problems. A summary of the findings on specific CG outcomes are presented below.

CG depression outcomes. Two studies found significant reduction in CGs’ reported depressive symptoms. Buckwalter, et al. compared controls receiving two informational home visits and reading material about dementia to an intervention of in-home training to reduce environmental stressors followed by phone consultation.26 The intervention resulted in reduced depressive symptoms at six months but not at 12 month follow-up. The second study examined individualized phone consultation focused on increasing self-efficacy compared with usual care.27 Self-reported CG depression scores improved with intervention, which also significantly increased CG reports of perceived self-efficacy. This study also reported higher CG satisfaction with care when telephone consults targeted self-efficacy.

Outcomes for other CG problems. Reduction in negative CG responses such as anger26 or upset/aversive response to problem behaviors28, 29 was reported for three programs that targeted environmental stressors through structured home visits.

Mood and problem behavior outcomes for CR. Some CG skills training studies reported significant improvements for CRs. One study focused on increasing the number of pleasant events scheduled for CRs, combined with teaching problem solving strategies to CGs, resulting in significant improvement in CGand CR ratings of the CR’s mood/depression.30 One study reported less decline in self-care for the CR under a protocol that provided occupational therapist home visits teaching problem solving to the CG for behavioral triggers, combined with training for the CR in performingADL.29 Two studies28, 29 reported significant reductions in CR behavior disturbance, but in one study this finding only held for dyads with non-spouse CGs. 28 One study reported a significantly larger proportion of CRs remained at home at 12 month follow-up when their CGs received nurse’s individual supportive counseling and strategies for behavior management, compared to controls who received phone contacts at comparably scheduled time points.31 However, there were no differences between groups in numbers of CRs institutionalized at this same follow-up, possibly indicating differences between groups at baseline, or other factors such as CR mortality, impacting on proportions remaining at home.

Limitations of the literature: There is some likely overlap between training offered in these studies and the clearly defined behavior management training techniques outlined in another section. For the most part, these good quality studies were well-controlled and characterized by intention to treat analysis when possible. There were high loss-to-follow-up rates in two studies, though they were not different in intervention and controls. However, unequal sample sizes, varying measures across studies, and differing recruitment strategies – some drawing from populations seeking help for dementia-related problems and others drawing from clinic populations – were common limitations.

#### GROUP SKILLS TRAINING, AND COMBINED INDIVIDUAL/GROUP SKILLS TRAINING

Summary impact of group skills training interventions: There is evidence that CG depression may improve with interventions that are individualized by in-home assessment and targeted to specific needs of the patient-CG dyad. Ancillary improvements in positive interactions and nurturing, reducing aversive and hostile CG responses to problem behaviors, reducing CG burden, and increasing CG self-efficacy are supported by single studies in he skills training domain.

Eight studies included in this grouping reported specific attempts to teach CGs new skills in group,31–36 combined individual/group settings,37, 38 or group sessions combined with transportable training media.39 Skills training included management of CR behavior problems, CG stress, or identifying environmental problems such as poor lighting that might contribute to CR strain or injury, and most interventions also provided psychoeducation about dementia. Two studies were conducted in the same sample.34, 35

The studies on group skills training and combined individual/group skills training allowed for examination of specific CG outcomes across studies, such as depression, mood, and other CG problems (Tables 4b and 4c). A summary of the findings on specific CG outcomes are presented below.

Table 4b RCTs of group skills training for caregivers of individuals with dementia

Study | Corbeil, et al. 1999^33^ | Hepburn, et al. 2007 (The Savvy Caregiver Program)39 | Hepburn, et al. 2006 (Partners in Caregiving)36 | Hepburn, et al. 2001 (The Minnesota Family Workshop)34 | Ostwald, et al. 1999^35^ | Coon, et al. 2003^32^
Population (N) | Coresident CGs of patients with probable or possible Alzheimer’s dementia with mild-moderate functional impairments. (N=87) | Family CGs of older adults with dementia recruited by agencies in 3 states.(N=30) There were 9 Savvy CG programs with groups ranging from 3 to 10 CGs. | 215 CGs giving care to a community-dwelling relative with dementia, who were expecting their CR to remain in the community for the 1 year study duration. | Primary CGs of community-dwelling individuals with dementia. (N=117) | Primary CGs of community-dwelling individuals with dementia who had displayed behavior problems. (N=117 of whom 94 dyads completed the program.) | Female CGs of community-dwelling individuals with physician-confirmed dementia (primarily Alzheimer’s and stroke). (N=169)
Intervention (N) | Active cognitive stimulation: 1-hour group sessions for 12 weeks, 6 days/week, offering training in activities to stimulate the minds of the CR. (N=28) | A 6-session, packaged program derived from the Minnesota Family Workshop that includes a trainer’s manual, CG manual, and CD-ROM or videotape. The packaged program can be offered by a variety of organizations or groups, with leadership typically provided by persons with an educational or clinical background. | Tx 1: Day-to-day caregiving (N=79) Tx 2: Decision-making (N=72) Each group met for 2 hours per week over 6 consecutive weeks. Curricula focused on developing a more clinical perspective on caregiving. Content and results were similar between Tx groups, and data were combined in the analysis. | Seven weekly training groups to improve coping and stress management; provision of information about dementia, develop strategies for care. Follow-up measures at 3 months after last training. (N=72) | Seven weekly training groups to improve coping and stress management; provision of information about dementia, develop strategies for care. Follow-up measures at 3 months after last training. (N=60) | Two intervention groups: 1) Anger management cognitive-based training (N=41) 2) Depression management cognitive behavioral training (N=45) - 8, 2-hour weekly group sessions, followed by 2 monthly booster sessions.
Control (N) | Passive stimulation: placebo intervention that included only passive activities (e.g. television) but had the same exposure to the researchers and followed the same time frames (television). (N=28) Wait-list control: interactions limited to 3 assessment contacts only; intervention was offered after 9-month study time frame. (N=31) | Wait-listed, no-attention control group (N=22), who were offered the training sessions after the 6-month intervention period. | Wait-list, no attention control group (N=64) with no contact with study staff except for data collection. Controls were enrolled in a PIC program after the completion of one-year data collection. | 5–6 month wait-list control. (N=45) Control group CGs participated in the training intervention after data had been gathered from the treatment group CGs. | 5–6 month wait-list control (N=34) | Wait-list control with initial assessment, 3–4 month follow-up assessment, and brief intermittent phone calls to maintain interest in study. Opportunity to participate in choice of intervention at end of 2nd assessment. (N=44)
CG outcome measures | Ways of Coping Scale-Revised Social Support Questionnaire of Schaefer Marital Needs Satisfaction Scale | A composite distress score computed as a weighted composite of 12 scales that include CES-D, Zarit Burden Scale, Bradburn affect scale, REACH anxiety scale | CES-D Zarit Burden Scale STAI BACS Decisional Conflict Scale Composite measure for distress | RMBPC BACS CES-D Zarit Burden Scale | CES-D Revised Caregiver Burden Scale RMBPC | RSCSE STAXI MAACL Ways of Coping Checklist-Revised BDI
CG results | At 9-month follow-up, CG satisfaction remained positive in the intervention group, but became negative in both the wait-list control and passive (placebo) groups. This improvement was statistically significant. | Distress at 6 months did not change among control CGs but decreased significantly among CGs in the Tx group. Tx CGs also reported a significantly greater sense of mastery (confidence) at 6 months. | Distress level increased and attitude about caregiving worsened among control CGs but remained stable at 6 months among Tx CGs. These advantages were no longer significant at 12 months. | Within treatment group, significant pre-post increase in nurturing score (less subordination of self to CR) and decreased reaction to behavior disturbance of CR. Compared to control group, intervention CG demonstrated increased nurturing, decreased reaction to behavior, lower depression and burden. | Reduced negative reaction to disruptive behavior and reduced burden in intervention group. | Significant reductions in anger/hostility and depression, and increase in self-efficacy in both intervention groups relative to control participants.
CR outcome measures | Memory and Behavioral Problems Checklist: measured as stressors for analysis of CG outcomes; not evaluated as outcomes of the intervention | ADL/IADL and disruptive behaviors measured as covariates; not evaluated as outcomes of the intervention. | --- | MMSE, Lawton ADL, and RMBPC were measured as covariates; not evaluated as outcomes of the intervention. | Cognitive Performance Test MMSE RMBPC | Not evaluated.
CR results | Not evaluated. | Not evaluated. | --- | Not evaluated. | No reduction in disruptive behaviors. | Not evaluated.
Comments | Small group sizes. | High attrition: 102 CGs were recruited into the study and completed baseline questionnaires, but only 51% retention and follow-up was achieved. | The study authors combined established scales to develop a composite distress measure; study author comments that the measure needs further testing and development. | Small sample. Population accessed as result of request for help with problem. | Dropouts and completers comparable on baseline demographics except for patient age. | Small but significant effect sizes. Participants not recruited from distressed population. Participation limited to women.

Abbreviations: ADL = activities of daily living; BDI = Beck Depression Inventory; BDRS = Blessed Dementia Rating Scale; CES-D = Center for Epidemiologic Studies Depression Scale; CG = caregiver; CMAI = Cohen-Mansfield Agitation Inventory; CR = care recipient; CSDD = Cornell Scale for Depression and Dementia; DRS = Dementia Rating Scale; FIM = Functional Independence Measure; GDRS = Geriatric Depression Rating Scale; HDRS = Hamilton Depression Rating Scale; IADL = Instrumental Activities of Daily Living scale; MAI = Multilevel Assessment Inventory; MBPC = Memory and Behavior Problems Checklist; MMSE = Mini Mental State Exam; POMS = Profile of Moods RIL = Record of Independent Living; SADS = Social Avoidance and Distress Scale; SR = systematic review; T1 = timepoint 1; T2 = timepoint 2; ZBI = Zarit Burden Interview.

Columns separated by a dashed line indicate that the two publications appear to be related and may be based on the same study.

Table 4c RCTs of combined individual skills training and group workshops for caregivers of individuals with dementia

Study | Bourgeois, et al. 2002^37^ | Burgio, et al. 2003^38^
Population (N) | Patients meeting NINCDS-ADRDA criteria for probable AD who also had mild behavioral disturbance, and their primary (spouse spending at least 8 hours per day with CR) and secondary (identified by primary CG, spent minimum 4 hours per day with patient) CGs. (N=76 enrolled, 63 completed the intervention period) | White and African American CGs of individuals with dementia and at least 3 problem behaviors. (N=118)
Intervention (N) | Two distinct 12-week skills training groups: 1) train CG to change CR behavior (N = 22); and 2) train CG to change own coping behaviors (N = 21). Initial meetings individual at-home assessment for two 1-hour visits, then 3-hour workshop in group, then 9 in-home visits for skills training. Follow-up measures 3 and 6 months post intervention. | Stress management and BMT skills training through group workshop, then 8 in-home BMT and cognitive restructuring sessions.
Control (N) | Comparable attention at workshops and in-home visits, but no training except didactics on stages of adjustment to dementia (and Problem Behavior Tracking forms reviewed at home visits. Provided generalized rather than individual information and empathy). (N=20) | Minimal support control.
CG outcome measures | Caregiver Strain Scale Spielberger Anger Expression Scale Spielberger Anxiety Inventory Caregiver Self-Efficacy Assessment Perceived Stress Scale CES-D Caregiver Health Index Caregiver mood - single item on a scale (1–9) | PAC LSNI CES-D
CG results | Mood ratings improved relative to controls in “self-change” CG group at post-test and 3 and 6-month follow- ups. Mood improved for “patient change” CGs relative to controls at posttest and 6-month follow-up. | No changes in depression or anxiety over 6 months. Both groups improved, reporting less bother and increased satisfaction with leisure activities.
CR outcome measures | MMSE OARS BEHAVE-AD | RMBPC
CR results | Reduced mean frequency of problem behaviors in “change patient behavior” group compared to control at post-test and 3 and 6-month follow-up. Reduction in behavior problems for “self-change” CG group at post-test and 6-month follow-up. | Significantly fewer problem behaviors in CR were noted by CGs in both treatment and control groups.
Comments | Research assistants blinded to group assignment administered measurements. Results indicate that dyads might benefit most from interventions specifically targeted to their needs (CG mood vs. care recipient behavior disturbance). | Staff not blinded to group assignment, but assessment and intervention always conducted by separate individuals. Six-month follow-up data include measures from CG whose CR had died – therefore, sample size changes on measures that were no longer appropriate. Different effects for African American versus White, and spouse vs. nonspouse CGs in secondary analyses.

Abbreviations: BEHAVE-AD = Behavioral Pathology in Alzheimer’s Disease rating scale; BMT = Behavior Management Training; CES-D = Center for Epidemiologic Studies Depression Scale; CG = caregiver; CR = care recipient; GQ-SR = good-quality systematic review; LSNI = Lubben Social Network Index; MMSE = Mini Mental State Exam; NINCDS-ADRDA = National Institute of Neurological and Communicative Diseases and Stroke – Alzheimer Disease and Related Disorders Association; OARS = Older Americans Resource and Services Multidimensional Functional Assessment Questionnaire; PAC = Positive Aspects of Caregiving scale; RMBPC = Revised Memory and Behavior Problem Checklist.

CG depression. CGs who received the intervention rated improved mood over control conditions in three of the six studies. A study of the Minnesota Family Workshop (MFW) program provided 14 hours of group skills training sessions to 75 CGs to increase coping and stress management skills; educate about dementia; and develop care strategies, compared to 45 participants in a wait-list control condition.34 This intervention resulted in significant improvement in self-ratings of CG burden, sense of nurturing, and aversive response to CR behavior. A subsequent study (N=215) by the same investigators assessed the long-term effects of a MFW-based program on CG distress, and found treatment benefits in CG attitude and distress at six months, but these effects were no longer significant at one year. 36 In another study, parallel intervention groups (one focused on anger management cognitive-behavioral intervention and one focused on depression cognitive-behavioral intervention) were compared to wait-list control with resulting significant reductions in depression and anger/hostility for both interventions compared to control.32 A third study investigated the impact of two distinct training groups, the first trained CGs to use behavior management techniques to reduce CR aversive behaviors, the alternate group taught CGs to change their own coping behaviors.37 Both interventions combined individualized in-home assessment and trainings with a three-hour group workshop to teach CG skills identified by the assessment. Both intervention groups were compared to a control group that received similarly scheduled workshops and in home visits with supportive empathy, but the didactics were general (e.g., information about stages of dementia) rather than individualized. The “self-change” group reflected significant improvements in CG depression at post-test, three month, and six month follow-up, while the “patient change” intervention resulted in significant CG depression reductions at post-test and six-month follow-up. Both intervention groups also rated improvements over control group participants in patient problem behaviors at posttest and six months, with the “patient change” group additionally documenting reduced problem behaviors at three months.

CG satisfaction with CR interactions. One study provided group workshops training CGs to stimulate the minds of their CR, and compared outcomes to a placebo group organized around a passive activity (e.g., watching television) and a control group that received assessment contacts only. On follow-up measures, CGs in the intervention group reported significantly higher satisfaction with interactions with the CR, though there were no significant effects for improved mood, burden, or quality of life.33

Other CG outcomes. One study combined a group workshop teaching stress management skills, with eight in-home behavior-management sessions, and compared this to minimal support control in which CGs were provided brief, structured telephone support calls with a target time of 15 minutes per call.38 Both intervention and control groups improved significantly over baseline measures, reporting less bother, increased satisfaction, and fewer problem behaviors at six-month post-test. An analysis by race determined that the skills-training intervention was more effective for reducing bother among African American CGs, whereas the minimal support control condition was more effective for White CGs. African American CGs were significantly less receptive to the minimal support phone contacts, with calls lasting an average of two fewer minutes in duration compared with calls to White CGs. The desire to institutionalize differed by race independently of intervention group: desire to institutionalize increased among White CGs, while scores for African American CGs on this measure remained stable.38

We examined an additional group skills training intervention suggested by a technical reviewer. The Savvy Caregiver Program is a transportable, packaged program for CGs of adults with dementia modeled on the MFW program.40 The package includes a trainer’s manual, a CG’s manual, and a CD-ROM or videotape meant to complement the CG manual. The program could be offered in the community by governmental, educational, medical, or social service provider organizations, and involves six two-hour group sessions led by a trainer with an educational or clinical background. A randomized trial of the Savvy Caregiver program included 52 CGs in three states, and assessed CG psychosocial outcomes after six months.39 The study reported significantly improved scores on measures of confidence and distress among CGs in the intervention group compared with wait-list controls. The attrition rate was high (nearly 50%), however, and the study authors cited logistic difficulties in retaining participation and collecting data. Although the generalizability of this study is consequently limited, the promising findings warrant more rigorous investigation of this packaged program on a larger scale.

Limitations of the literature: The studies reviewed here represent skills-focused training in groups or combined with individual training, but there is likely to be considerable variability in methods and deployment of the groups. The skill level of the trainer, the setting, frequency and duration of contacts, the validity of the training material and relevance to the outcome variables of interest, and method of recruitment are likely to contribute to unmeasured variance and differences in outcomes across studies. Intervention and control group sizes tended to be small and loss-to-follow-up high, a situation common to studies with frail and/or distressed populations. Studies tended to differ on policy for inclusion/exclusion of data from follow-up analyses if the CR had died during the study; the degree to which this could confound measures such as burden and depression is suspect but unknown.

#### INDIVIDUAL, GROUP, AND COMBINED INDIVIDUAL/GROUP SUPPORTIVE COUNSELING

Summary impact of individual, group, and combined individual/group supportive counseling interventions: Neither individual supportive counseling nor group supportive interventions on their own demonstrated clear superiority over control groups for CG depression. A combined individual/group approach resulted in delayed institutionalization for the CR and long-term improvements in mood and self-rated health for the CG, but this was a very resource-intensive intervention and replicability should be evaluated.41–44 Ancillary improvements in affective regulation for coping and aversive reaction to CR behavior disturbance were supported in single studies. None of these interventions demonstrated group treatment effects for CG burden.

Studies were included in this group when supportive behaviors were an intentional focus of treatment. Six studies in this collection employed supportive interventions, including empathy, emotional support, and identifying sources of support in the environment.41–43, 45–47

One of the six studies reported on individual supportive counseling with cognitive-behavioral problem solving focus by a nurse care manager.45 Two studies focused on CG group counseling protocols with: education about dementia, problem-solving, stress management, provision of emotional support, cognitive reappraisal;46 and coping strategies, problem-solving, and identifying social supports.47 These three studies are shown in Table 5a. There were no significant treatment effects on CG depression, burden, or anxiety for any of these three studies. However, Haley and colleagues reported that CGs trained in affective regulation for coping showed significant improvements in affective regulation,46 and Hebert, et al. documented significantly less CG aversive reaction to CR behavior disturbance with coping/problem-solving supportive interventions.47

Table 5a RCTs of individual counseling or group support for caregivers of individuals with dementia

Study | Roberts, et al. 1999^45^ | Haley, Brown & Levine 1987^46^ | Heber, et al. 2003^47^
Population (N) | CGs of cognitively-impaired home-dwelling individuals. (N=77) | Family CGs of community-dwelling individuals with dementia. (N=54) | Primary CGs of community dwelling individuals with dementia and one+ behavior problem; CGs report moderate to severe burden on scale. (N=118 in final analysis after death and institutionalization of 25 CR)
Intervention (N) | Individual counseling: Nurse provided up to 10 supportive, individualized problem-solving (cognitive behavioral) counseling sessions over 6 months. Measures at baseline, 6 and 12 months. (N=38) | Group 1: structured provision of information about dementia, emotional support, and problem solving. (N=21) Group 2: similar to Group 1 but added material on stress-management, relaxation, cognitive reappraisal. (N=22) Both groups: 7 weekly 1.5 hour sessions followed by assessment; then 2 sessions 2 weeks apart; then final group after 1 month follow-up assessments. | Support group: 15, 2-hour weekly psychoeducational group sessions teaching cognitive coping strategies, problem-solving and identifying supports. Strong focus on behavior problems. Assessed blindly before randomization and again at 16 weeks. (N=79)
Control (N) | No counseling, complete measures at baseline, 6 and 12 months. (N=39) | Waitlist control assessed at equivalent intervals to intervention group. Later given opportunity to participate in identical groups to study. (N=11) | Referred to existing, traditional support group through Alzheimer’s Association or other health care group in Quebec. (N=79)
CG outcome measures | Caregiver Burden Interview PAIS Health Utilization Questionnaire Duke Social Support Interview Indices of Coping | BDI LSIZ ECR HDLF | RMBPC ZBI STAI Inventory of Socially Supportive Behaviors 14-item Ilfeld Psychiatric symptoms Index
CG results | No significant treatment effects for distress, burden, or psychosocial adjustment. | No significant group effects on measures of psychological and social functioning. Use of emotional discharge for coping, and use of affective regulation for coping showed significant effects for training. | No treatment group differences in burden, depression, or anxiety. Significantly greater reduction in reaction to behavior disturbance for study intervention group.
CR outcome measures | Reisberg’s Stages of Cognitive Decline; Barthel Index; % institutionalized within 1 year | Not evaluated. | RMBPC
CR results | 18% in intervention vs. 31% in control were institutionalized within 1 year of follow-up. That all CGs who were sons were randomized to control group may confound these results. | Not evaluated. | RMBPC change, treatment vs. control: Frequency − 0.07 vs. 0.12 (p=0.06) Disruptive behaviors frequency: − 0.06 vs. 0.15 (p=0.08)
Comments | Some whose relatives were institutionalized or died prior to follow-up measures completed questionnaires, others did not. Dropouts indicated more psychological distress at baseline. | Participants not referred for distress, levels of baseline distress highly variable across participants. | Excluded from final analyses 1 CG whose CR had died (1% of control group) and CGs whose CR had been institutionalized (15% of treatment group; 18% of controls)

Abbreviations: BDI = Beck Depression Inventory; CG = caregiver; CR = care recipient; ECR = Elderly Caregiver Family Relationship; GQ-SR = good-quality systematic review; HDLF = Health and Daily Living Form; LSIZ = Life Satisfaction Index; PAIS = Psychological Adjustment to Relative’s Illness; RMBPC = Revised Memory and Behavior Problem Checklist; STAI = State Trait Anxiety Disorder; ZBI = Zarit Burden Interview.

Three studies that combined individual counseling and support group sessions are shown in Table 5b. One study by Zarit, Anthony, & Boutselis (N=119) compared an intervention combining eight weeks of individual and family therapy, to eight weekly support group sessions, with both compared to wait list control (eight weeks, then enrollment into group).48 All groups, including the control arm, responded with improved mood and burden; there were no group treatment effects.

Table 5b RCTs of combined individual counseling and support group for caregivers of individuals with dementia

Study | Mittelman, et al. 2004 (NYU Caregiver Intervention) 42, 44, 49 | Mittelman, et al. 1995^43^ Mittelman, et al. 1996^41^ | Zarit, Anthony, & Boutselis 1987^48^
Population (N) | Spouse CGs of home-dwelling individuals with Alzheimer’s disease, naming one additional relative in area. (N=406, with 223 completing 5 year follow-up) | Spouses of community-dwelling individual with diagnosis of Alzheimer’s dementia, naming additional relative in area. (N=206) | Family member primary CG of individuals with dementia. (N=184 initial assessment, 119 completed)
Intervention (N) | Six sessions of individual and family counseling, weekly support groups after 4 months with availability of crisis counseling as needed. Topics individually determined, include BMT, support, enhancing communication. Interviewed every 4 months 1st year, then every 6 months until 2 years after death of CR or refusal. (N=203) | Six sessions of individual and family counseling, weekly support groups after 4 months with availability of crisis counseling as needed. Topics individually determined, include BMT, support, enhancing communication. Interviewed every 4 months 1st year, then every 6 months until 2 years after death of CR or refusal. (N=103) | 1) Support group, 8 weekly sessions providing information about disease, problem-solving, BMT, identifying supports. (N=44) 2) Individual and family counseling, same format as above but individually and family-focused. (N=36)
Control (N) | Usual care at NYU Alzheimer’s Disease Center (N=203) | Usual care at NYU Alzheimer’s Disease Center (N=103) | Wait-list control assigned to intervention after 8 weeks with follow-up evaluation; post-treatment data included in assessment of effects at 1 year. (N=39)
CG outcome measures | GDRS Self-rated health assessed using a questionnaire adapted from OARS | 1995: GDRS MBPC Stokes Social Networks Scale Test adapted from OARS FACES III Questionnaire 1996: Kaplan-Meier survival analysis Older Americans Resources and Service questionnaire Geriatric Depression Scale MBPC | Changes in CG’s reports of stress; improvement in management of CR’s problem behaviors; increased use of social support; CG’s perception of treatment benefits. Revised Burden Interview BSI MBPC Caregiver Change Interview
CG results | Significantly greater change on depression measure in intervention group compared to usual care with intervention group improving. Significant treatment group effects of lower depression scores maintained through year 3 of study. Self-rated health was significantly better in the treatment group during the first 2 years of follow-up. | Intervention group significantly less depressed at 8 month measure (Mittelman 1995). | All groups, including control, reported subjective improvement, lower burden, and lower psychiatric symptoms over time, no significant group effects.
CR outcome measures | Time to nursing home placement. GDS measured but analyzed as a covariate only. | 1996: GDRS Time to institutionalization | Not evaluated.
CR results | 28.3% reduction in nursing home placement with Tx compared with control dyads (adjusted HR=0.717, p=0.025). Reduction in time from baseline to nursing home placement was 557 days: usual care = 1,209 days; enhanced counseling and support group = 1,766 days (model-predicted median). | Median length of stay at home from baseline was significantly longer for treatment group. Risk of institutionalization lower for intervention group, particularly for mild-moderate dementia, | Not evaluated.
Comments | Baseline depression significantly lower in treatment group. Used ITT analysis. Results robust across CG gender and severity of dementia. Unblinded counselors conducted follow-up assessments. | Used ITT analysis. | High attrition after first assessment (36%) attributed to family members’ expressed disappointment that intervention was focused on them, not cure or help for CR.

Abbreviations: BMT = behavior management training; BSI = Brief Symptom Inventory; CG = caregiver; CR = care recipient; GDS = Global Deterioration Scale; GDRS = Geriatric Depression Rating Scale; GQ-SR = good-quality systematic review; HR = hazard ratio; ITT = intention-to-treat; MBPC = Memory and Behavior Problems Checklist; NYU = New York University; OARS = Older Americans Resource and Services Multidimensional Functional Assessment Questionnaire.

Columns separated by a dashed line indicate that the two publications appear to be related and may be based on the same study.

In a series of reports, Mittelman and colleagues reported on a trial of the New York University Caregiver Intervention conducted between 1987 and 2006. The intervention involved four months of individual family counseling followed by weekly support groups offering psychoeducation on BMT, identifying social supports, and enhancing communication, compared to usual care at an Alzheimer’s Disease Center.41–43, 49 CGs in these studies responded to the intervention with significantly reduced depression, sustained as long as three years into follow-up.42, 43 This approach combining individualized assessment with supportive group sessions also significantly reduced risk of institutionalization for the CR, with longer median length of stay in the home compared to usual care.41, 49 The initial analyses included 206 CGs,41, 43 and subsequent analyses of the continuing trial (N=406) reported long-term improvements for the CG in social support, stress appraisals, and self-rated health, as well as delayed nursing home placement for the CR.42, 42, 49

Limitations of the literature: There is definitional and functional overlap with case management, BMT, and skills-focused studies reported earlier; supportive counseling often included problem-solving and teaching of skills, and all interventions likely included some element of supportive empathy, even when that was not the targeted intervention. Some studies excluded CGs whose loved one was institutionalized or had died during the study from the final analysis, while others included some but not all CGs who no longer had a CR with dementia in the home at the time of final follow-up measurement. Recruitment strategies differed in that some studies sampled from CG populations that were seeking help for an identified behavior problem, while others drew from a more general Alzheimer’s Association or dementia clinic population.

### WIDELY CITED PSYCHOSOCIAL INTERVENTION STUDIES THAT WERE EXCLUDED FROM THIS REVIEW

We reviewed a total of 78 primary studies gleaned from 11 systematic reviews for this evidence synthesis. We excluded 48 studies when: they were not RCTs (N = 12); sample size was less than 50 (N = 23); not enough information was supplied to quality rate (3); they had group differences at baseline (1), and/or they had differential loss to follow-up (1).

Six of the 48 excluded studies have been cited frequently, occurring in five or six of the 11 systematic reviews. These six studies used a variety of interventions and reported mixed results. One study (N=36 CGs) used a six-week behavioral intervention for sleep problems and found significant improvements in sleep patterns at three-month follow-up, but no effects on CG mood or burden.50 Another study provided counseling and information about psychological and practical home-based techniques, such as orientation and memory management strategies, to 30 patients with newly diagnosed dementia and their families. At 18-month follow-up, depression and anxiety had increased among CGs in the control group but not in the treatment group, and more CRs in the control group had been institutionalized compared with the treatment group.51 An RCT (N=41 CGs) of a structured support group that held two-hour sessions weekly for eight weeks found no effects on CG mood or burden.52 A study that provided CG education, stress management, and coping skills training in 14 sessions over 28 weeks reported significant reductions in CR behavioral disturbance in the intervention group (N=14), and significant CG reductions in depression in the intervention group compared with controls (N=28).53 An eight-week intervention RCT (N=35 CGs) that compared a skills-training cognitive-behavioral group intervention to a support group that emphasized information-giving and social exchanges found no differences in CG burden or psychological distress.54

### TECHNOLOGY-BASED INTERVENTIONS

Summary impact of technology-based interventions: There is insufficient evidence from controlled empirical studies on the effectiveness of technology-based interventions. Uncontrolled studies suggest that GPS location systems for wandering behavior may improve patient function and safety as well as reduce CG depression, burden, and stress. Robust trials with sufficient follow-up are needed to determine the feasibility, effectiveness, and cost-effectiveness of ICT interventions.

Three systematic reviews assessed the effectiveness of networked information and communications technology (ICT) interventions in supporting CGs, and included studies published through 2005,^55^ 2006,^56^ and 2007.^57^ Although two reviews56, 57 were largely descriptive and did not appraise the quality of the included studies, because they provided a comprehensive overview of ICT services available for individuals with dementia and their CGs, we included them in this review.

One review57 included 15 papers that described five interventions: 1) COMPUTERLINK, a non-internet based computer network with an unmoderated forum that offers e-mail, an electronic encyclopedia, anonymous question and answers to a nurse moderator, and a decision support module; 2) Telephone-Linked Care (TLC), a computer-mediated automated telephone support system that offers automated CG stress-monitoring and counseling information, message and bulletin board support group, and a respite call for CGs; 3) Computer-Telephone Integration System (CTIS), a computerized system using Spanish and English text and voice screen phones to facilitate messaging, local information access, and support group calls; 4) AlzOnline, which offers an Internet library, message board, expert forum, and web- and telephone-based education classes; and 5) Caring for Others, an Internet-based and group videoconferencing discussion forum. The TLC and CTIS interventions were part of the REACH study.58 The studies were RCTs of six to 18 months duration, except for one study that used a single-group pre/post-test design to evaluate the AlzOnline intervention. The sample sizes in each study ranged from 21 to 77 per group, and the comparator interventions varied in each study from no intervention, minimal support, information booklets, and family therapy. The reviewers noted that the interventions provided benefits to stress and depression for some but not all CGs, and that intervention usage varied between studies and was generally low.57 The lack of quality appraisal of included studies was a limitation in this review.

A meta-analysis55 combined three RCTs to determine the pooled effect of the COMPUTERLINK,59 TLC,58 and CTIS60 interventions on CG depression. Although increases in subjective measures of social support, knowledge, decision-making confidence, and mental health were observed among the studies, the meta-analysis showed no significant overall effect of the technology-based interventions on depression. Heterogeneity in the types of interventions and comparators make it difficult to combine the findings across studies. The reviewers assessed the methodological quality of included studies and found that the overall quality was poor, citing unclear methods for randomization; lack of blinding; and potential for selection bias.55

A descriptive review of ICT-based services identified four websites and 20 publications that addressed the needs of CRs and CGs with regard to symptoms.56 The interventions included multimedia support programs for CGs delivered via Internet, and telecare devices such as videophones to facilitate communication between CGs and healthcare providers. Interventions directed at the CR included devices and applications such as memory aids that provide reminders for daily tasks and medicine. The evidence consisted largely of case studies and small (n<50) pre- and post-test/post-test only studies, although there was one large RCT (n=299) of a multimedia Internet-based support program that provided text material and videos that modeled positive caregiving strategies. The RCT found significant improvement after 30 days in CG depression, anxiety, strain, stress, self-efficacy, intention to seek help, and perception of positive aspects of caregiving.61 Uncontrolled studies of electronic memory aids for the CR and other assistive technologies reported improvements in carrying out daily activities and reductions of everyday memory and planning failures, suggesting the potential for such devices to support independence in the CR and reduce CG burden.

This review also identified 13 interventions that focused largely on wandering behaviors.56 Devices included GPS-location systems; boundary alarms activated by wristband; floor-lighting systems activated upon wandering detection; communication systems instructing the patient to return to bed after failure to return for a pre-defined period of time; cooking monitoring systems; and alarms alerting the CG of wandering behavior. The evidence consisted of case studies, cross-sectional studies, or single-group, pre- and post-test/post-test only studies, and the settings included residential homes, nursing homes, and hospital settings. As one example, the Safe House Project used a single-group, post-test study of 19 families to evaluate a web-based monitoring system that included power, water, and door sensors as well as cameras. Fourteen out of 16 CGs in this study reported that the “system made life easier (e.g., peace of mind; added security; easier to keep track of individual with dementia)” and 11 out of 16 reported that “the system positively changed how the CG spends his/her time, e.g., more free time and more time for self.”62 The devices in other studies were generally found to be effective, reliable, and successful in detecting wandering, locating lost patients, and reducing patient and CG stress. More rigorous trials are needed to assess the feasibility and effectiveness of these devices in broader use within VA.

Limitations of the literature: Although there is potential for some assistive technology devices to reduce CG burden by improving the independent function of the patient and by increasing patient safety, the interventions included in these reviews were generally limited in design by the lack of a control group. Heterogeneity in the types of interventions makes it difficult to combine the findings across studies.

### RESPITE CARE

Summary impact of respite care: Although a systematic review of respite care found small, statistically-significant improvements on some outcome measures, the evidence on how respite affects the health and well-being of CGs was inconsistent. Institutional/overnight respite promoted better sleep patterns in CGs during the period of respite; but there were no marked improvements in health and well-being in comparison to control groups, or compared to CG’s baseline state associated with respite services of any form. The vast majority of CGs, however, frequently expressed high levels of satisfaction, and generally felt that respite services brought them various benefits, despite little evidence of significant or sustained reductions in measures of stress, depression, and burden. Many studies reported CGs’ beliefs that respite enabled them to continue caring. Day care services were best studied, and the evidence for benefit for CGs and CRs was mixed. Time freed up by day care did not necessarily reduce the total amount spent on caregiving.

A 2004 systematic review compiled for the UK National Coordinating Center for NHSNHS Delivery and Organization Research & Development reviewed the effectiveness and cost-effectiveness of respite services for CGs of people with dementia.63 The review identified 45 articles published from 1985 through 2003 that reported results on several forms of respite services. Fifteen of the 45 studies were conducted in the US, and 16 were conducted in the UK. The remaining studies were conducted in Europe (n=8), Canada (n=4), and Australia (n=2). Day care was the intervention most frequently studied.

The review examined the following outcomes:

1. Effectiveness in relation to CG’s health and well-being
2. Effectiveness in relation to CRs’ health, well-being, and dementia-related symptoms
3. Impact on the use of other services
4. Cost-effectiveness in relation to CG’s and CRs’ health and well-being

Given the comprehensive and in-depth nature of the NHS evaluation, we quote findings directly from the NHS report on the effectiveness of each type of respite care, including cost-effectiveness when evidence was available. In this report we refer to the findings on four forms of respite care that are available or might be feasible to provide in VA:

1. Day care – planned services provided outside of the home, not involving overnight stays
2. In-home respite services – involves a paid care worker coming into the family home to “sit” with the care recipient
3. Institutional/overnight respite – allows breaks away from the family home for the CR for one or more nights
4. Video respite – uses a tailored video to occupy the CR’s attention, thus freeing up the CG’s time for a mini-break

#### DAY CARE SERVICES

The NHS report identified 21 studies on day care services. Below is the summary of findings on day care services:

“Many CGs placed a high value on day care services, perceiving benefits for both themselves and the person with dementia. However, problems relating to day care attendance (e.g., lack of transportation, or the experience/belief that the patient became more confused when moved from home) acted as barriers to usage for some CGs. Few studies attempted to collect the views of people with dementia themselves, but there was some evidence to suggest patients enjoy the company, the sense of belonging and the activities provided. The evidence about the impact on CGs of using day care was unclear. Some studies showed demonstrable improvements in physical health, stress and psychological well-being, yet others showed no change. The evidence about the impact on people with dementia of day care attendance was unclear. Some studies showed improvements or stabilization, whereas others showed no positive effects. The mixed results are likely to reflect issues such as: weaknesses/differences in study design; the wide range of outcome measured used; study timescales; differences and/or deterioration in disease severity; differences in the frequency and amount of day care used. Time freed up by day care did not necessarily reduce the total amount spent on caregiving. There was some evidence to suggest that day care attendance might have a preventative effect on entry to long-term care. Two of four economic evaluations suggested that day care might be cost-saving, whereas the other half suggested that day care might provide greater benefits but at a higher cost as compared to standard care. All four studies suggested that the benefits of day care might be similar or greater than those achieved through standard care.”63

#### IN-HOME RESPITE

The NHS report identified eight studies on in-home respite services. The studies used a variety of methods and considered different types of outcomes. The in-home visits typically lasted three to four hours at most, and the maximum number of hours in a given week was 19, although most services provided fewer hours. Three of the studies examined how CGs used their time during periods of in-home respite, and found little evidence that CGs used the break to engage in social or recreational activities. Instead, CGs usually did shopping or other chores; men often used the free hours to do paid work; and some CGs used the respite time for additional help with caring tasks such as lifting, bathing, and other personal hygiene tasks. One study compared in-home respite and day care on how CGs used their time. CGs spent less time on caregiving on respite days than on non-respite days with in-home respite care, whereas day care users spent more time caregiving on respite days than on non-respite days, probably in preparing the CR for going to the day care center.63

Below is a summary of the findings on in-home respite care:

“Carers reported high levels of satisfaction with in-home respite services. Satisfaction appeared to be closely linked to their perceptions of the benefits that the service bought to their relative, and the quality of care provided. Carers reported that they would have liked the service more often, and liked visits to last longer as the relatively short periods of respite constrained the type of activity that could be undertaken.

“None of the studies were able to demonstrate statistically significant positive effects of in-home respite on a range of measures. The evidence suggested that in-home respite could assist in maintaining family routines, and roles, and the dementia sufferer’s sense of self.

“It is difficult to separate the impact of in-home respite on the demand for other types of respite care, or in reducing or delaying entry into long-term care, as most carers in these studies were accessing a range of different services.

“No evidence was retrieved in relation to the cost-effectiveness of in-home respite.”63

#### INSTITUTIONAL/OVERNIGHT SERVICES

The NHS report identified 12 studies on institutional/overnight services, including two studies conducted at VA hospitals.64, 65 One VA study assessed CG burden and depression 14 days before respite, the day of patient discharge, and 14 days post-respite, among 125 CGs whose CR had been scheduled for a two-week hospital admission for respite care. The study found transient improvement in CG burden and depression that was statistically significant at the time of discharge, but by two weeks post-respite care, these measures were notsignificantlydifferent from their values two weeks prior to respite admission. Another VA study surveyed 25 CGs by telephone three days before respite admission, three days before respite discharge, and 14 days after respite discharge, and similarly found a significant reduction in psychological distress that was short-lived.65 The lack of a control group was a limitation in these studies.

The overall findings of the NHS report on institutional/overnight respite care were as follows: “Physical and emotional benefits were seen as worthwhile when set against the difficulties of organizing institutional/overnight services. Institutional and overnight services were seen to help in some way, but other short-term breaks were seen as more beneficial to the CR. Standards of care and quality of service influence use of services. There was some evidence that CRs returned home in a worse state, but also that medical conditions could be diagnosed during breaks. Although some CGs experienced guilt in using services, others reported that services helped them to continue in their caring role. There appeared to be a major benefit to sleep, with CGs experiencing increased and better-quality sleep. There was mixed evidence on the impact of services in relation to ADL, behavior and dependency (in the CR), but it is difficult to unravel the potentially negative effects of respite from the natural progression of the disease. There was little evidence that services reduced the demand for long-term placements.”63

Overall, there appear to be mixed benefits from institutional/overnight respite care. Sleep is improved in the CG, but the disruption to the CR’s routine may be problematic. It is questionable, however, that the disease would progress enough to affect ADLs and behavior during the two-week duration, as Arksey, et al. suggests.

#### VIDEO RESPITE

The evidence on video respite compiled by the HTA report63 is based on two studies by the same investigators.66, 67 In both studies a videotape was for general viewing by persons with dementia, rather than customized for individuals, although separate tapes were made for men, women, and people from African-American, Jewish, and Hispanic backgrounds. The purpose of the videotape was to capture the CR’s attention to a degree that would provide respite for the CG. In the first study, the video consisted of a 33-minute tape recorded by an actor/actress who speaks to the demented viewer, tells short stories, sings songs, and asks questions about specific subjects such as favorite activities, music, and holidays. The study found that most of the viewers with dementia remained seated and were paying attention and verbally responding throughout the viewing time.66 The second study examined whether there was a difference in how 12 individuals with Alzheimer’s watched a 20-minute videotape in a group setting compared to viewing it alone, and found that there was greater participation and response to “requests” made on the tape in a solitary setting compared with a group setting, although in both settings, viewers demonstrated at least moderate levels of interest and enjoyment.67 There was no evidence on the effects of video respite on CG burden or CR outcomes.

Limitations of the literature: Most of the studies were not based on RCT design, and in some studies no control group was used. A number of different instruments were used to measure outcomes in the studies, and there is a wide range of intended consequences of respite care and short-term breaks. In some instances the purpose may be to assist CGs to “let go” and allow their relative to enter long-term care, while in other cases, the goal might be to support CGs to actively provide care for longer. The impact of an intervention might be difficult to capture due to the magnitude of the effect and the number of effects possible. There is a great deal of heterogeneity in this body of literature.

### RECENT AND ONGOING RESEARCH STUDIES

In response to our e-mail solicitation to VA researchers and listservs, authors of unpublished and recently published studies shared with us the following

- A six-month feasibility study of implementing the REACH VA intervention among 24 home-based primary care (HBPC) programs in the VHA system found decreases in CG burden, depression, and time spent in caregiving; as well as decreases in CR behavior problems. REACH VA is based on the National Institute on Aging/National Institute of Nursing Research (NIA/NINR) funded REACH II study, and provides CG support and skills training in safety, behavior management, and self-care via 12 in-home and telephone sessions, and five telephone support group sessions. The analysis found that the VHA costs of delivering the full intervention would be $2.93 per day over six months, and that satisfaction and perception of benefit from the intervention were high among both staff and CGs.68
- Partners in Dementia Care (PDC) is an ongoing HSR&D funded intervention that is a collaboration between local VA medical centers and Alzheimer’s Association chapters. The intervention is delivered by care coordinators from each partner organization and includes a shared patient and CG assessment and ongoing action plan. PDC tests a phone-based Care Coordination Intervention that uses coaching, empowerment, and a consumer-directed approach when working with Veterans and family CGs. The Intervention assists with 1) accessing services and informal support, 2) providing information and education about dementia and caregiving, and 3) providing emotional support. The study of over 500 Veterans is in the data analysis phase, and will compare psychosocial outcomes for patients and CGs and Veteran health service use across intervention and control settings.69
- REACH OUT, a condensed version of the REACH II intervention that included four home visits and three phone calls over four months, was found to be feasible for use by social service agency personnel. The intervention was delivered to 272 dementia CGs, and improvements were seen in CG subjective burden, mood, social support, and health; and also in CR mood and behavior problems.70
- An uncontrolled pilot study of the TLC screen program examined user satisfaction and changes in CG burden, health care utilization, and costs after 12 months. The TLC program included a screen-telephone system that provided access to education, support, monitoring, and various VHA resources; as well as personal assistance from a nurse care coordinator and a support person. The study included 113 CGs of individuals with dementia. There were no significant changes after 12 months in CG outcomes including burden, depression, and ability to cope, although decreases in facility costs, hospital admissions, and hospital days of care were noted. CGs indicated that they were more satisfied with the care-coordination aspect of the program compared with the education or the monitoring.71
- Pilot evaluations are currently underway to determine effects on CG burden and well-being of using remote sensor technology to monitor Veterans in the HBPC program. The technology would be used to convey information about the CR’s daily activities to both the CR and CG, as well as the HBPC nurse. Another ongoing study by the same investigator will determine the effects of an online Long Term Care (LTC) Resource Guide and Shared Decision Making Tool on CG well-being and LTC knowledge.72
- A recently completed RCT of the Telehealth Education Program, a telephone based education and support group designed for CGs of Veterans with dementia, found short-term savings in health care costs, despite that there were no significant effects on CG burden.73
- A proposed RCT of Preventing Aggressive Behavior in Demented Patients (PAVeD), a six- to eight-session, home-based psychoeducational intervention for individuals with dementia and pain and their CGs. The (PAVeD) intervention aims to prevent the development of aggression in demented individuals with pain. The intervention addresses the recognition and treatment of pain in the CR, increasing pleasant activities, and improving patient-caregiver communication.69
- A recently completed study of the Stress-Busting Program (SBP) for Family Caregivers found improvements in CG health, social function, anxiety, anger/hostility, depression, perceived stress, and burden over the course of the two-month intervention and at two and four months post-intervention. This was measured by questionnaires, biofeedback techniques, and blood assays. The study included 202 CGs of individuals with Alzheimer Disease and Related Disorders (ADRD). The intervention involved psychoeducational support groups that met 1½ hours per week for nine weeks, and stress management techniques were also taught during the sessions. In post-intervention interviews, CGs reported that the relaxation and stress management techniques enabled them to manage stress more effectively. CGs also expressed that the interaction and companionship with other CGs was a beneficial aspect of the program. CGs who completed the SBP commonly expressed that the interaction and companionship with other CGs was the most beneficial aspect of the program. CGs also reported that the relaxation and stress management techniques enabled them to manage stress more effectively.74
- An ongoing project entitled CARE-Plus includes CGs within the community and the VA system, and randomizes CGs to one of three groups: a psychoeducational control group, a multi-component group designed to teach specific skills to manage neuropsychiatric symptoms, and a third group that receives the multi-component intervention as well as additional self-efficacy enhancing techniques. A telehealth approach for use by home-based CGs, combined with initial and booster home visits, would be a potential application for the intervention in the VA system.75

## KEY QUESTION #2. What are adverse effects of CG interventions?

The systematic review of respite care63 found evidence in one study76 to suggest that CGs using day care service actually spend more time on caregiving activities on respite days than on non-respite days, usually in preparing the CR for the visit or transporting the CR to the day care setting.

In studies of institutional/overnight respite, some CGs reported that the respite break had adversely affected the CRs, and that the disruption to their routine had increased anxiety and confusion.63 In one study,77 some CGs reported an increase in short-term workload because the CR’s continence worsened on return home, whereas other CGs reported a loss of mobility for the CR because wheelchair use by the services had created a dependency. Another drawback identified by CGs in this study was a concern about standards of care, and 10% of the sample (n=167) who tried institutional/overnight breaks decided not to use the service again based on quality of service. In a small (n=25) study of institutional/overnight respite services, over half of CGs reported feeling sad or lonely while the patient was in the hospital, and one-fifth felt guilty and reported criticism from friends and relatives for allowing relief admission.78

We found no evidence of adverse effects from other CG interventions based on the systematic reviews yielded by our search, and the primary studies on psychosocial interventions we examined.