# REFERENCES

1 Veterans Health Administration Office of the Assistant Deputy Under Secretary for Health Policy and Planning. Projections of the prevalence and indidence of dementias including Alzheimer's Disease for the total, enrolled, and patient veteran populations aged 65 or over. 2004. http://www4.va.gov/HEALTHPOLICYPLANNING/reports1.asp.
2 Administration on Aging’s Alzheimer’s Disease Supportive Services Program. Annotated Bibliography: Evidence-based interventions that target people with ADRD or their caregivers. http://www.aoa.gov/AoARoot/AoA_Programs/HCLTC/Alz_Grants/docs/EB2010.pdf.2010.
3 Pinquart M, Sorensen S. Helping caregivers of persons with dementia: which interventions work and how large are their effects?. Int Psychogeriatr. Dec. 2006;18(4):577-595. [pmid: 16686964].
4 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force. A review of the process. American Journal of Preventive Medicine. 2001;30(3S):21-35. [pmid: 11306229].
5 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
6 Brodaty H, Gresham M, Luscombe G. The Prince Henry Hospital dementia caregivers’ training programme. Int J Geriatr Psychiatry. Feb. 1997;12(2):183-192. [pmid: 9097211].
7 Folstein MF, Folstein SE, McHugh PR. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. Nov. 1975;12(3):189-198. [pmid: 1202204].
8 Hughes CP, Berg L, Danziger WL, Coben LA, Martin RL. A new clinical scale for the staging of dementia. Br J Psychiatry. Jun. 1982;140:566-572. [pmid: 7104545].
9 Drummond MF, Mohide EA, Tew M, Streiner DL, Pringle DM, Gilbert JR. Economic evaluation of a support program for caregivers of demented elderly. Int J Technol Assess Health Care. 1991;7(2):209-219. [pmid: 1907599].
10 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial.[Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I39; PMID: 17116914]. Ann Intern Med. Nov 21. 2006;145(10):727-738. [pmid: 17116917].
11 Holland JM, Currier JM, Gallagher-Thompson D, Holland JM, Currier JM, Gallagher-Thompson D. Outcomes from the Resources for Enhancing Alzheimer’s Caregiver Health (REACH) program for bereaved caregivers. Psychology & Aging. Mar. 2009;24(1):190-202. [pmid: 19290751].
12 Gitlin LN, Winter L, Dennis MP, et al. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. Jama. Sep 1. 2010;304(9):983-991. [pmid: 20810376].
13 Castro CM, Wilcox S, O’Sullivan P, et al. An exercise program for women who are caring for relatives with dementia. Psychosom Med. May–Jun. 2002;64(3):458-468. [pmid: 12021419].
14 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. Jama. May 10. 2006;295(18):2148-2157. [pmid: 16684985].
15 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care: a randomized, controlled trial.[Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I31; PMID: 17116913]. Ann Intern Med. Nov 21. 2006;145(10):713-726. [pmid: 17116916].
16 Eloniemi-Sulkava U, Notkola IL, Hentinen M, Kivela SL, Sivenius J, Sulkava R. Effects of supporting community-living demented patients and their caregivers: a randomized trial. Journal of the American Geriatrics Society. Oct. 2001;49(10):1282-1287. [pmid: 11890485].
17 Miller R, Newcomer R, Fox P. Effects of the Medicare Alzheimer’s Disease Demonstration on nursing home entry. Health Serv Res. Aug. 1999;34(3):691-714. [pmid: 10445898].
18 Newcomer R, Yordi C, DuNah R, Fox P, Wilkinson A. Effects of the Medicare Alzheimer’s Disease Demonstration on caregiver burden and depression. Health Serv Res. Aug. 1999;34(3):669-689. [pmid: 10445897].
19 Teri L, McCurry SM, Logsdon R, et al. Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. Dec. 2005;45(6):802-811. [pmid: 16326662].
20 Gormley N, Lyons D, Howard R. Behavioural management of aggression in dementia: a randomized controlled trial. Age Ageing. Mar. 2001;30(2):141-145. [pmid: 11395344].
21 Teri L, Gibbons LE, McCurry SM, et al. Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. Jama. Oct 15. 2003;290(15):2015-2022. [pmid: 14559955].
22 Burns R, Nichols LO, Martindale-Adams J, et al. Primary care interventions for dementia caregivers: 2-year outcomes from the REACH study. Gerontologist. Aug. 2003;43(4):547-555. [pmid: 12937333].
23 Gallagher-Thompson D, Gray HL, Tang PC, et al. Impact of in-home behavioral management versus telephone support to reduce depressive symptoms and perceived stress in Chinese caregivers: results of a pilot study. Am J Geriatr Psychiatry. May. 2007;15(5):425-434. [pmid: 17463192].
24 Gonyea JG, O’Connor MK, Boyle PA, Gonyea JG, O’Connor MK, Boyle PA. Project CARE: a randomized controlled trial of a behavioral intervention group for Alzheimer’s disease caregivers. Gerontologist. Dec. 2006;46(6):827-832. [pmid: 17169938].
25 Farran CJ, Gilley DW, McCann JJ, et al. Efficacy of behavioral interventions for dementia caregivers. West J Nurs Res. Dec. 2007;29(8):944-960. [pmid: 17596639].
26 Buckwalter KC, Gerdner L, Kohout F, et al. A nursing intervention to decrease depression in family caregivers of persons with dementia. Arch Psychiatr Nurs. Apr. 1999;13(2):80-88. [pmid: 10222636].
27 Bass DM, Clark PA, Looman WJ, et al. The Cleveland Alzheimer’s managed care demonstration: outcomes after 12 months of implementation. Gerontologist. Feb. 2003;43(1):73-85. [pmid: 12604748].
28 Gerdner LA, Buckwalter KC, Reed D. Impact of a psychoeducational intervention on caregiver response to behavioral problems. Nursing Research. Nov–Dec. 2002;51(6):363-374. [pmid: 12464756].
29 Gitlin LN, Corcoran M, Winter L, Boyce A, Hauck WW. A randomized, controlled trial of a home environmental intervention: effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. Feb. 2001;41(1):4-14. [pmid: 11220813].
30 Teri L, Logsdon RG, Uomoto J, McCurry SM. Behavioral treatment of depression in dementia patients: a controlled clinical trial. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Jul. 1997;52(4):P159-166.
31 Wright LK, Litaker M, Laraia MT, DeAndrade S. Continuum of care for Alzheimer’s disease: a nurse education and counseling program. Issues Ment Health Nurs. Apr–May. 2001;22(3):231-252. [pmid: 11885210].
32 Coon DW, Thompson L, Steffen A, et al. Anger and depression management: psychoeducational skill training interventions for women caregivers of a relative with dementia. Gerontologist. Oct. 2003;43(5):678-689. [pmid: 14570964].
33 Corbeil RR, Quayhagen MP, Quayhagen M. Intervention effects on dementia caregiving interaction: a stress-adaptation modeling approach. J Aging Health. Feb. 1999;11(1):79-95. [pmid: 10848143].
34 Hepburn KW, Tornatore J, Center B, Ostwald SW. Dementia family caregiver training: affecting beliefs about caregiving and caregiver outcomes. Journal of the American Geriatrics Society. Apr. 2001;49(4):450-457. [pmid: 11347790].
35 Ostwald SK, Hepburn KW, Caron W, Burns T, Mantell R. Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. Jun. 1999;39(3):299-309. [pmid: 10396888].
36 Hepburn KW, Lewis M, Narayan S, et al. Partners in Caregiving: a psychoeducation program affecting dementia family caregivers’ distress and caregiving outlook. Clinical Gerontologist. 2006;29(1):53-69.
37 Bourgeois MS, Schulz R, Burgio LD, Beach S. Skills training for spouses of patients with Alzheimer’s Disease: outcomes of an intervention study. Journal of Clinical Geropsychology. 2002;8(1):53-73.
38 Burgio L, Stevens A, Guy D, et al. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. Aug. 2003;43(4):568-579. [pmid: 12937335].
39 Hepburn K, Lewis M, Tornatore J, et al. The Savvy Caregiver program: the demonstrated effectiveness of a transportable dementia caregiver psychoeducation program. J Gerontol Nurs. Mar. 2007;33(3):30-36. [pmid: 17378189].
40 Hepburn KW, Lewis M, Sherman CW, et al. The savvy caregiver program: developing and testing a transportable dementia family caregiver training program. Gerontologist. Dec. 2003;43(6):908-915. [pmid: 14704391].
41 Mittelman MS, Ferris SH, Shulman E, Steinberg G, Levin B. A family intervention to delay nursing home placement of patients with Alzheimer disease. A randomized controlled trial. Jama. Dec 4. 1996;276(21):1725-1731. [pmid: 8940320].
42 Mittelman MS, Roth DL, Coon DW, et al. Sustained benefit of supportive intervention for depressive symptoms in caregivers of patients with Alzheimer’s disease. Am J Psychiatry. May. 2004;161(5):850-856. [pmid: 15121650].
43 Mittelman MS, Ferris SH, Shulman E, et al. A comprehensive support program: effect on depression in spouse-caregivers of AD patients. Gerontologist. Dec. 1995;35(6):792-802. [pmid: 8557206].
44 Mittelman MS, Roth DL, Clay OJ, et al. Preserving health of Alzheimer caregivers: impact of a spouse caregiver intervention. Am J Geriatr Psychiatry. Sep. 2007;15(9):780-789. [pmid: 17804831].
45 Roberts J, Browne G, Milne C, et al. Problem-solving counseling for caregivers of the cognitively impaired: effective for whom?. Nursing Research. May–Jun. 1999;48(3):162-172. [pmid: 10337847].
46 Haley WE, Brown SL, Levine EG. Experimental evaluation of the effectiveness of group intervention for dementia caregivers. Gerontologist. Jun. 1987;27(3):376-382. [pmid: 3609812].
47 Hebert R, Levesque L, Vezina J, et al. Efficacy of a psychoeducative group program for caregivers of demented persons living at home: a randomized controlled trial. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Jan. 2003;58(1):S58-67.
48 Zarit SH, Anthony CR, Boutselis M. Interventions with care givers of dementia patients: comparison of two approaches. Psychology & Aging. Sep. 1987;2(3):225-232. [pmid: 3268213].
49 Mittelman MS, Haley WE, Clay OJ, et al. Improving caregiver well-being delays nursing home placement of patients with Alzheimer disease. Neurology. Nov 14. 2006;67(9):1592-1599. [pmid: 17101889].
50 McCurry SM, Logsdon RG, Vitiello MV, Teri L. Successful behavioral treatment for reported sleep problems in elderly caregivers of dementia patients: a controlled study. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Mar. 1998;53(2):P122-129.
51 Moniz-Cook E, Agar S, Gibson G, Win T, Wang M. A preliminary study of the effects of early intervention with people with dementia and their families in a memory clinic. Aging Ment Health. 1998;2(3):199-211.
52 Hebert R, Leclerc G, Bravo G, Dirouard D, Lefrancois R. Efficacy of a support group programme for caregivers of demented patients in the community: a randomized controlled trial. Archives of Gerontology and Geriatrics. 1994;18:1-4. [pmid: 15374309].
53 Marriott A, Donaldson C, Tarrier N, Burns A. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer’s disease. Br J Psychiatry. Jun. 2000;176:557-562. [pmid: 10974962].
54 Gendron C, Poitras L, Dastoor D, Perodeau G. Cognitive-Behavioral Group Intervention for Spousal Caregivers: Findings and Clinical Considerations. Clinical Gerontologist. 1996;17(1):3-19.
55 Thompson CA, Spilsbury K, Hall J, Birks Y, Barnes C, Adamson J. Systematic review of information and support interventions for caregivers of people with dementia. BMC Geriatr. 2007;7:18. [pmid: 17662119].
56 Lauriks S, Reinersmann A, Van der Roest HG, et al. Review of ICT-based services for identified unmet needs in people with dementia. Ageing Res Rev. Oct. 2007;6(3):223-246. [pmid: 17869590].
57 Powell J, Chiu T, Eysenbach G. A systematic review of networked technologies supporting carers of people with dementia. J Telemed Telecare. 2008;14(3):154-156. [pmid: 18430288].
58 Mahoney DF, Tarlow BJ, Jones RN. Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. Aug. 2003;43(4):556-567. [pmid: 12937334].
59 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer’s disease. Nursing Research. May–Jun. 1995;44(3):166-172. [pmid: 7761293].
60 Eisdorfer C, Czaja SJ, Loewenstein DA, et al. The effect of a family therapy and technology-based intervention on caregiver depression. Gerontologist. Aug. 2003;43(4):521-531. [pmid: 12937331].
61 Beauchamp N, Irvine AB, Seeley J, et al. Worksite-based internet multimedia program for family caregivers of persons with dementia. Gerontologist. Dec. 2005;45(6):793-801. [pmid: 16326661].
62 Kinney JM, Kart CS, Murdoch LD, Conley CJ. Striving to provide safety assistance for families of elders - The Safe House project. Dementia: the international journal of social research and practice. 2004;3(3):351-370.
63 Arksey H, Jackson K, Croucher K, et al. Review of respite services and short-term breaks for carers for people with dementia. London. NHS SDO. 2004.
64 Adler G, Ott L, Jelinski M, Mortimer J, Christensen R. Institutional respite care: benefits and risks for dementia patients and caregivers. International Psychogeriatrics. 1993;5(1):67-77. [pmid: 8499576].
65 Larkin JP, Hopcroft BM. In-hospital respite as a moderator of caregiver stress. Health Soc Work. May. 1993;18(2):132-138. [pmid: 8288141].
66 Lund DA, Hill RD, Caserta MS, Wright SD. Video Respite: an innovative resource for family, professional caregivers, and persons with dementia. Gerontologist. Oct. 1995;35(5):683-687. [pmid: 8543227].
67 Caserta MS, Lund DA. Video Respite in an Alzheimer’s care center: Group versus solitary viewing. Activities, Adaptation & Aging. 2002;27(1):13-28.
68 Nichols LO, Martindale-Adams J. Resources for Enhancing Alzheimer’s Caregivers Health in the VA (REACH VA). Unpublished abstract. personal communication.
69 Kunik ME. Personal communication.
70 Burgio LD, Collins IB, Schmid B, et al. Translating the REACH caregiver intervention for use by area agency on aging personnel: the REACH OUT program. Gerontologist. Feb. 2009;49(1):103-116. [pmid: 19363008].
71 Dang S, Remon N, Harris J, et al. Care coordination assisted by technology for multiethnic caregivers of persons with dementia: a pilot clinical demonstration project on caregiver burden and depression. Journal of Telemedicine & Telecare. 2008;14(8):443-447. [pmid: 19047456].
72 Reder S. Personal communication.
73 Wray LO, Shulan MD, Toseland RW, Freeman K, Vasquez BE, Gao J. The effect of telephone support groups on costs of care for Veterans with dementia. Unpublished abstract. personal communication.
74 Miner-Williams D. Relaxation Therapy for Alzheimer’s Caregivers. Personal communication.
75 O’Connor MK. Personal communication.
76 Berry GL, Zarit SH, Rabatin VX. Caregiver activity on respite and nonrespite days: a comparison of two service approaches. Gerontologist. Dec. 1991;31(6):830-835. [pmid: 1800257].
77 Levin E, Moriarty J, Gorbach P. Better for the Break. London. HMSO and National Institute for Social Work. 1994.
78 Pearson ND. An assessment of relief hospital admissions for elderly patients with dementia. Health Trends. Nov. 1988;20(4):120-121. [pmid: 10318143].
79 Nichols LO, Chang C, Lummus A, et al. The cost-effectiveness of a behavior intervention with caregivers of patients with Alzheimer’s disease. Journal of the American Geriatrics Society. Mar. 2008;56(3):413-420. [pmid: 18179480].
80 Roberts J, Browne G, Gafni A, Varieur M, Loney P, De Ruijter M. Specialized continuing care models for persons with dementia: a systematic review of the research literature. Can J Aging. 2000;19:106-126.
81 Brodaty H, Green A, Koschera A. Meta-analysis of psychosocial interventions for caregivers of people with dementia. Journal of the American Geriatrics Society. May. 2003;51(5):657-664. [pmid: 12752841].
82 Schulz R, Burgio L, Burns R, et al. Resources for Enhancing Alzheimer’s Caregiver Health (REACH): overview, site-specific outcomes, and future directions. Gerontologist. Aug. 2003;43(4):514-520. [pmid: 12937330].
83 Thompson CCA, Spilsbury K. Support for carers of people with Alzheimer’s type dementia. Cochrane Database of Systematic Reviews. 2009(2).
84 Schulz R, O’Brien A, Czaja S, et al. Dementia caregiver intervention research: in search of clinical significance. Gerontologist. Oct. 2002;42(5):589-602. [pmid: 12351794].
85 Gallagher-Thompson D, Lovett S, Rose J, et al. Impact of psychoeducational interventions on distressed family caregivers. Journal of Clinical Geropsychology. 2000;6(2):91-110.