# DISCUSSION

We conducted a critical assessment of systematic reviews and recently published studies on interventions for dementia CGs. We identified several promising interventions, but there was considerable variability in outcomes evaluated across interventions, and no single type of intervention was unequivocally effective on any given outcome of interest. Though the body of evidence for most interventions was limited, the following points highlight potentially promising approaches:

- The evidence on how respite affects the health and well-being of CGs is inconsistent, but respite care appears to be valued by CGs and may offer them short term benefits. Institutional/overnight respite promoted better sleep patterns in CGs during the period of respite, although there were no marked improvements in health and well-being in comparison to control groups. Short term respite care, however, may be more burdensome than beneficial for the dyad in terms of effort, preparation time, and disruption to routine.
- ICT interventions, such as GPS-location systems for wandering behavior, may improve patient function and safety as well as reduce CG burden, although current evidence is based largely on uncontrolled studies.
- Although findings were inconsistent, a limited body of evidence suggests that BMT may enhance CG well-being, depression and burden, and CR quality of life, particularly when BMT is augmented by increasing CR exercise or CG self-care behaviors.
- Individual skills training showed benefit in some studies. CG depression was ameliorated in two studies, although there were no effects on other measures of CG burden. In two other studies, disruptive behavior in the CR appeared to diminish when CGs received structured training to identify behavioral triggers and to modify the environment to reduce stress.
- CG depression may improve with both group and combined individual/group skills training interventions, particularly when the interventions are individualized by in-home assessment and targeted to specific needs of the patient-CG dyad. Ancillary improvements in positive interactions and nurturing, reducing aversive and hostile CG responses to problem behaviors, reducing CG burden, and increasing CG self-efficacy are supported by single studies.
- CG depression may respond to treatments that offer a combination of individualized counseling and group support to the CG. The combined individual/group approach also resulted in delayed institutionalization for the CR in one study. These findings are supported by a series of publications by Mittelman and colleagues, and would be strengthened by replication elsewhere. Ancillary improvements in affective regulation for coping and aversive reaction to CR behavior disturbance were supported in single studies. The effects of individual counseling and group support may vary with the skill level of the trainer, the setting, frequency and duration of contacts, and the training materials used.
- Combined exercise for CR and BMT for the CG may improve physical health and mood for the CR, although impact on CG burden, mood, quality of life, and delay of CR institutionalization has not been demonstrated.
- Supportive CG counseling based on individual assessment appears to have robust positive effects on the rate of institutionalization of the CR and on CG depression, maintained as long as three years into follow-up.
- Overall, the strongest support appears for multicomponent interventions that are designed after individual in-home assessment and tailored to the specific needs of the CG/CR dyad. Improvements in CG confidence in caregiving skills, well-being, sense of burden, stress, and mood can be seen with combined approaches. Although there is no clear evidence that institutionalization of the CR may be delayed, it does appear that behavioral symptoms of dementia can be reduced through multicomponent interventions for at least four months after intervention, and this likely improves the home atmosphere for both CR and CG.

The feasibility of implementation and cost analyses of these interventions need to be assessed within VA. Individualized programs may be the most effective but would require more resources of staff to evaluate the dyad and generate a tailored program. One cost benefit analysis of the REACH II multicomponent intervention in Memphis, Tennessee79 indicated that training in dementia problem areas, behavior management techniques, and supportive contact can result in sparing dementia CGs an hour a day from caregiving tasks, at an estimated cost of $5 per day.

Loss to follow up appeared problematic for many of the studies in this review, and may be clinically important. This may highlight issues of intervention acceptability to dementia CGs, and reasons for dropout should be assessed and help guide future implementation efforts in this field.

We noted inconsistent and sometimes disappointing findings among the variety of interventions for dementia CGs. For example, the lack of effect for respite care in reducing CG burden and premature CR institutionalization seems intuitively surprising. It is possible that the relentless decline and challenge of dementia poses a stable negative impact that overwhelms more transient improvements in mood, burden, quality of life, and support for maintaining CRs in the home. This may indicate that the definition of what constitutes meaningful change in this field and whether the instruments used are sensitive enough to detect it need to be reevaluated.

Alternatively, the measures used to define the psychosocial outcomes of depression, burden, coping, quality of life, and CR behavior problems as constructs may lack adequate sensitivity to detect meaningful change in the context of dementia. For example, across the 30 primary studies reported here, the Center for Epidemiologic Studies Depression Scale (CES-D) was used to measure depression in nine studies, and one-third of those studies reported a significant reduction in CG depression in the intervention group. It is possible that the benefits of the interventions employed in the studies were important to the CGs but too subtle to result in enduring change on the CES-D. We attempted to examine the performance of measures for CG depression, burden, and CR behavior problems across the 37 studies reviewed here, but the samples were too small to derive strong conclusions about whether specific measures were more likely to detect improvements. Only four measures were used in six or more studies; they were associated with a study reporting significant improvement from baseline among CGs in the following proportions: Geriatric Depression Rating Scale 43%; CES-D 33%; Zarit Burden Inventory 17%; Memory and Behavior Problems Checklist (MBPC) or Revised Memory and Behavior Problems Checklist (RMBPC) 33%. As early as 1987, Zarit, et al. wrote that global ratings of distress and burden may not reflect the changes or possible benefits that CGs may be experiencing, yet these measures continue to be used widely.

The evidence on psychosocial interventions is limited by differences in the interventions used across studies. Furthermore, many studies assessed complex interventions and it was difficult to determine with confidence which aspect of the intervention was effective. However, the addition of the REACH studies following expert panel commentary increased the perspective of this review, and may suggest that the specific intervention or combination of interventions is not as important as the role of individual assessment and tailoring of interventions to the needs of the dyad through multiple modalities. Viewed through this lens, intervention variability and adaptability may be an important feature of a successful intervention, permitting responsiveness to variation across individuals.

There was potentially more compromising variations in recruitment strategies and analytic methods across studies. For example, some studies excluded from final analysis the data from CGs whose CR had died or moved to institutional care settings 47 while others did not.80 Some studies drew from a distressed population seeking assistance where response to treatment may be more evident,34 while others sampled from general clinic or Alzheimer’s Association membership rosters.46

Outcome measures and interventions varied widely across studies, but complications also arise when these aspects overlap imperfectly. We had difficulty sorting the studies into discrete intervention groups, and noted, for example, that skills-based interventions often included aspects of the more precisely defined behavior management training, and that supportive counseling similarly offered components of skills training as part of the intervention. Psychosocial interventions do not lend themselves to the same precise sorting and control as a medication trial might. From published reports, it was not possible to compare adherence to therapeutic protocol, or an individual interventionist’s ability to form rapport with the subjects across studies, or assess how these factors contributed to outcomes. It is likely these instrumentation issues varied considerably across studies.

A further source of discrepancy in results may stem from individual variation. Across studies, we noted a number of factors that should be controlled for in future studies and considered when weighing treatment options for CG/CR dyads in dementia. More severe CG depression at baseline can result in differential dropout and poor treatment adherence.13, 26 Burgio, et al. report differential effects for African American CGs compared to Caucasian American CGs: a skills-training intervention was more effective for reducing bother among African American CGs, whereas minimal support phone contacts were more effective for White CGs.38 Interventions can have different effects for spousal CGs than for nonspouses28, 38 and for female versus male CGs.28 Brodaty and colleagues reported they solicited from CGs which part of the program had been most useful and found “marked variety in the answers, suggesting that different components were helpful for different CGs.”6

There were also limitations to generalizing findings from the review of technology-based interventions. The reviews were largely descriptive and did not appraise the quality of the included studies. Older systematic reviews that performed quality appraisal of RCTs contained evidence from four RCTs on phone and computer-based interventions that may no longer be relevant as technology develops. However, the studies reviewed provide a comprehensive overview of ICT services available for individuals with dementia and their CGs.

Given that the efficacy of an intervention varies with the individual, individualized multicomponent treatments may well hold the most promise. This conclusion is consistent with the pattern of ndings reported in this synthesis project. We agree with the conclusions of Brodaty, et al. in their fi 2003 systematic review that multicomponent, individualized treatments targeting specific problems identified by the CG while offering combined the most identifiable meaningful change in CG mood and coping.81 This conclusion is also aligned with Schulz et al.,82 who wrote in an overview of the REACH studies that “Many caregiving interventions involve several treatment elements aimed at simultaneously addressing multiple problems. Multicomponent interventions delivered in high doses are generally more effective than more narrowly targeted interventions…[however] we believe a ‘one size interventions is likely to be ineffective” (p. 519).

This review is also limited by the dates of literature covered by the good quality systematic reviews we included. The most recent reviews included in our synthesis were published in 2009; and the most recent literature searches conducted by these reviews extended through 2007 for technology-based interventions,57 and through 2005 for psychosocial interventions.83 Given the broad scope of our review, we examined previous systematic reviews in search of compelling evidence of significant benefit from CG interventions. Because previous reviews and the trials they identified did not show compelling evidence of benefit in any particular intervention, we did not conduct a systematic search for recently published RCTs. To address the likelihood that newer trials published since 2007 have found strong evidence of benefit but were not considered in our review, we added newer original studies to this overall document upon the recommendation of our expert review panel. We felt the studies recommended by our expert panel represented highly regarded, well-constructed RCTs that added new strength to the literature. In fact, the quality of studies emerging from the REACH program caused us to reappraise the strength of multicomponent interventions, while studies added on recommendation also persuaded us that case management appears to be a stronger contributor to CG coping and quality of life than originally assessed. While the process of beginning with a review of reviews and then adding specific new studies recommended by expert peers may have resulted in a less systematic representation of the recent literature (published after 2006), we tried to minimize that problem by including a wide variety of experts on our panel, and also included the AoA Compendium to bolster comprehensiveness.

We noted that many studies eliminated by our quality rating have been included in four, five, or even six major systematic reviews frequently cited in the field. Psychosocial studies of vulnerable populations tend to be laden with challenges from the outset, and there may be a need to use less stringent quality criteria in order to assess the contributions of the field. In order to narrow our search to the best quality data, we identified the studies that have been frequently cited, and assessed their quality using standard criteria and group consensus. This approach also has its weaknesses. There may be good quality studies reviewed in poor quality reviews that were not captured in this project. Also, subtle, transient, individual subject responses may be a more appropriate indicator of effectiveness when intervening with dementia CR/CG dyads, and current evidence synthesis conventions evaluating statistical significance may not be ideally equipped to isolate these small but potentially clinically meaningful effects.

The distinction between clinical and statistical significance is important to the topic of dementia CG interventions. Schulz and colleagues (2002) conducted a systematic review with the explicit intent of evaluating the clinical importance of outcomes for dementia CGs.84 They required a priori that an effect has statistical significance before evaluating the clinical significance, which they defined by one of four indicators: 1) improvement towards normal functioning in clinical symptoms; 2) improvement in quality of life; 3) importance of an outcome to society; and 4) social validity (extent to which research participants and experts judge the interventions and outcomes to be acceptable). They concluded that psychosocial interventions appeared promising for clinically significant outcomes in CG depression, based on clinical improvements seen in two of 24 studies reviewed.30, 85 Psychosocial interventions also appeared to be promising for targeting CG anxiety (four of seven studies showed small clinical improvements). Small positive effects were noted for CG quality of life, but the heterogeneity of interventions rendered it difficult to attribute outcomes to specific causes, and there was no overall good standard for judging what constitutes a clinically significant change in this cluster. Delay of institutionalization (an important social outcome) was clinically important in six of seven heterogeneous interventions reviewed. The authors noted that most studies met criteria for social validity, but those ratings were possibly biased as subjects may have felt obligated to report positive comments to please researchers or to justify their own challenges in participating. In sum, methods for determining clinical significance remain somewhat unstandardized, but scrutiny of dementia CG interventions reveals some promise of clinical utility for CG depression/anxiety, and evidence that outcomes of these interventions are socially important.

## FUTURE RESEARCH RECOMMENDATIONS

Based on our examination of primary studies used in previous systematic reviews, CG interventions that appear to be effective tend to be individually-tailored treatments that are more resource-intensive, such as BMT and individual skills training. Our informal survey of recently completed and ongoing studies using VA e-mail listservs identified preliminary studies of psychosocial interventions (REACH OUT;70 REACH VA;68 Stress-Busting Program74) and technology-based interventions (Telehealth Education Program;73 TLC71) that found improvements in CG burden with some of the interventions, and short-term savings in health care costs in one study.73 Studies of other psychosocial interventions (PAVeD; PDC69) and technology-based interventions72 have been proposed or are underway. In order to determine the feasibility of implementation, effectiveness, and cost-effectiveness of CG interventions within VA settings, future studies should evaluate different implementation strategies, evaluate interventions in different settings, and evaluate methods for improving participant retention. Given some of the methodologic weaknesses in past studies, future studies should use rigorous study designs, sufficient sample size, and appropriate duration of follow-up.

The wide range of outcomes used to evaluate the effects of CG interventions reflects the diversity in what CGs and researchers consider effective. In addition to their review of published studies on respite care, Arksey, et al.63 conducted a qualitative consultation with multiple stakeholders, including CGs, CRs, and health and social care professionals. Key objectives of the consultation were to examine the gaps in the literature and to examine whether the outcomes that CGs value are the same as, or similar to, those used in the research literature. The contributors to the consultation generally felt that respite was too complex to be evaluated by one or two measures of effectiveness. They proposed a range of qualitative and quantitative indicators against which they felt the effectiveness of respite services should be measured. Proposed quantifiable measures included the following: 1) a comparison of the CR’s health, both physical and mental, on admission and discharge, within the context of clear individual health goals; 2) a similar assessment of the health of the CG; and 3) the impact of activities/stimulation on the CR’s behavior, sleep patterns, ADL, etc.”63

Similar studies of CG perceptions with regard to other interventions would potentially offer a rich source of inspiration for the development of tools that measure what we hope to measure in this field: evidence that the CG has perceived and responded to useful intervention that improves the quality of experience within the here and now. We need to understand what interventions to offer to a CG who is depleted by months of challenging daily assistance to a loved one with dementia, and evaluate interventions that might impact those outcomes for cost and utility. Qualitative studies to identify outcomes that are important to individuals with dementia and their CGs within the VA system would serve future research and policy for promoting the best welfare of aging veterans and their community CGs.