# Appendices

APPENDIX A INCLUSION/EXCLUSION CRITERIA

APPENDIX B QUALITY RATING CRITERIA FOR SYSTEMATIC REVIEWS

APPENDIX C USPSTF QUALITY RATING CRITERIA FOR RANDOMIZED CONTROLLED TRIALS (RCTS) AND COHORT STUDIES CRITERIA

APPENDIX D ABBREVIATIONS

APPENDIX E REVIEWER COMMENTS AND RESPONSES