# ABBREVIATIONS

AA: African American
AD: Alzheimer’s Disease
ADL: Activities of daily living
ADRDA: Alzheimer Disease and Related Disorders Association
AHRQ: Agency for Healthcare Research and Quality
AoA: Administration on Aging
BACS: Beliefs about Caregiving Scale
BDI: Beck Depression Inventory
BDRS: Blessed Dementia Rating Scale
BEHAVE: Behavioral Pathology in Alzheimer’s Disease Rating Scale
BMT: Behavior management training
CES-D: Center for Epidemiologic Studies Depression Scale
CG: Caregiver
CMIA: Cohen-Mansfield Agitation Inventory
CI: Confidence interval
COPE: Care of Persons with Dementia in their Environments
CQLI: Caregiver Quality of Life Instrument
CR: Care recipient
CSDD: Cornell Scale for Depression in Dementia
CTIS: Computer-Telephone Integration System
DRS: Depression Rating Scale
DSC: Dementia Steering Committee
ECR: Elderly Caregiver Family Relationship
EPC: Evidence Based Practice Center
ESP: Evidence-based Synthesis Program
FIM: Functional Independence Measure
GDRS: Geriatric Depression Rating Scale
GDS: Global Deterioration Scale
GPS: Global Positioning System
GQ-SRs: Good quality systematic reviews
HBPC: Home Based Primary Care
HDLF: Health and Daily Living Form
HDRS: Hamilton Depression Rating Scale
HSR&D: Health Services Research and Development
HTA: Health Technology Assessment
ITT: Intention-to-treat
IADL: Instrumental Activities of Daily Living scale
ICT: Information and Technology Intervention
LSIZ: Life Satisfaction Index
LSNI: Lubben Social Network Index
LTC: Long-term care
MAACL: Multiple Affect Adjective Checklist
MADDE: Medicare Alzheimer’s Disease Demonstration and Evaluation program
MAI: Multilevel Assessment Inventory
MBPC: Memory and Behavior Problems Checklist
MMSE: Mini Mental State Exam
MFW: Minnesota Family Workshop
N: Number
NHS: National Health Service
NIA/NINR: National Institute on Aging/National Institute of Nursing Research
NINCDS: National Institute of Neurological and Communicative Diseases and Stroke
NPI: Neuropsychiatric Inventory
NYU: New York University
OARS: Older Americans Resource and Services Multidimensional Functional Assessment Questionnaire
OGEC: Office of Geriatrics and Extended Care
PAC: Positive Aspects of Caregiving scale
PAIS: Psychological Adjustment to Relative’s Illness
PAVeD: Preventing Aggressive Behavior in Demented Patients
PCI: Patient Care Index
PDC: Partners in Dementia Care
PHQ9: Patient Health Questionnaire-9 Item
PIC: Partners in Caregiving
POMS: Profile of Moods States
QALY: Quality of adjusted life years
QOL/QoL: Quality of life
RAGE: Rating Scale for Aggressive Behavior in the Elderly
RCT: Randomized controlled trial
REACH: Resources for Enhancing Alzheimer’s Caregiver Health
RIL: Record of Independent Living
RMBPC: Revised Memory and Behavior Problem Checklist
RSCSE: Revised Scale for Caregiving Self-Efficacy
SADS: Social Avoidance and Distress Scale
SBP: Stress-Busting Program
SF-36: Short-form health survey
SIP: Sickness Impact Profile
SR: Systematic Review
SSCQ: Short Sense of Competence Questionnaire
STAI: State Trait Anxiety Inventory
STAXI: State Trait Anger Expression Inventory
T1: Timepoint 1
T2: Timepoint 2
TLC: Telephone-Linked Care
Tx: Treatment
UK: United Kingdom
VA: Veterans Affairs
VAMC: Veterans Affairs Medical Center
VHA: Veterans Health Administration
VISN: Veterans Integrated Service Network
ZBI: Zarit Burden Interview