# INCLUSION/EXCLUSION CRITERIA

Inclusion/Exclusion Criteria form