# REFERENCES

1 Veterans Health Administration Office of the Assistant Deputy Under Secretary for Health for Policy and Planning. Projections of the prevalence and incidence of dementias including Alzheimer’s Disease for the total, enrolled, and patient veteran populations aged 65 or over. 2004. http://www4.va.gov/HEALTHPOLICYPLANNING/reports1.asp.
2 Yu W, Ravelo A, Wagner TH, et al. Prevalence and costs of chronic conditions in the VA health care system. Med Care Res Rev. Sep. 2003;60(3 Suppl):146S-167S. [pmid: 15095551].
3 U.S. Preventive Services Task Force. Screening for dementia: recommendations and rationale. Am 91, 93, 95. Sep. 2003;103(9):87.
4 UK National Screening Committee. Policy on screening for Alzheimer’s Disease. 26/03/09. http://www.screening.nhs.uk/alzheimers.
5 Boustani M, Callahan CM, Unverzagt FW, et al. Implementing a screening and diagnosis program for dementia in primary care. Journal of General Internal Medicine. Jul. 2005;20(7):572-577. [pmid: 16050849].
6 Boustani M, Watson L, Fultz B, et al. Acceptance of dementia screening in continuous care retirement communities: a mailed survey. Int J Geriatr Psychiatry. Sep. 2003;18(9):780-786. [pmid: 12949845].
7 Hopkins JS, Watson LC, MB, Perkins T, Fox C. What do healthy older adults think about dementia screening?. J Amer Geriatr Soc. 2006;54:S189.
8 Boustani M, Perkins AJ, Fox C, et al. Who refuses the diagnostic assessment for dementia in primary care?. Int J Geriatr Psychiatry. Jun. 2006;21(6):556-563. [pmid: 16783796].
9 O’Connor DW, Pollitt PA, Hyde JB, Brook CP, Reiss BB, Roth M. Do general practitioners miss dementia in elderly patients?. Bmj. Oct 29. 1988;297(6656):1107-1110. [pmid: 3143447].
10 Sternberg SA, Wolfson C, Baumgarten M. Undetected dementia in community-dwelling older people: the Canadian Study of Health and Aging. J Am Geriatr Soc. Nov. 2000;48(11):1430-1434. [pmid: 11083319].
11 Valcour VG, Masaki KH, Curb JD, Blanchette PL. The detection of dementia in the primary care setting. Arch Intern Med. Oct 23. 2000;160(19):2964-2968. [pmid: 11041904].
12 National Chronic Care Consortium and the Alzheimer’s Association. Tools for early identification, assessment, and treatment for people with Alzheimer’s disease and dementia. 1998. revised June 2003. A publication of the Chronic Care Networks for Alzheimer’s Disease Initiative Available at wwwalzorg/national/documents/ccn-ad03pdf.
13 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov 10. 2003;3:25. [pmid: 14606960].
14 Whiting P, Harbord R, Kleijnen J, Whiting P, Harbord R, Kleijnen J. No role for quality scores in systematic reviews of diagnostic accuracy studies. BMC Med Res Methodol. 2005;5:19. [pmid: 15918898].
15 Mitchell AJ. The clinical significance of subjective memory complaints in the diagnosis of mild cognitive impairment and dementia: a meta-analysis. Int J Geriatr Psychiatry. Nov. 2008;23(11):1191-1202. [pmid: 18500688].
16 Lavery LL, Lu SY, Chang CC, Saxton J, Ganguli M. Cognitive assessment of older primary care patients with and without memory complaints. J Gen Intern Med. Jul. 2007;22(7):949-954. [pmid: 17453265].
17 Ganguli M, Du Y, Rodriguez EG, et al. Discrepancies in information provided to primary care physicians by patients with and without dementia: the Steel Valley Seniors Survey. Am J Geriatr Psychiatry. May. 2006;14(5):446-455. [pmid: 16670249].
18 Carr DB, Gray S, Baty J, Morris JC. The value of informant versus individual’s complaints of memory impairment in early dementia. Neurology. Dec 12. 2000;55(11):1724-1726. [pmid: 11113230].
19 Tatsch MF, Bottino CM, Azevedo D, et al. Neuropsychiatric symptoms in Alzheimer disease and cognitively impaired, nondemented elderly from a community-based sample in Brazil: prevalence and relationship with dementia severity. Am J Geriatr Psychiatry. May. 2006;14(5):438-445. [pmid: 16670248].
20 Lyketsos CG, Lopez O, Jones B, Fitzpatrick AL, Breitner J, DeKosky S. Prevalence of neuropsychiatric symptoms in dementia and mild cognitive impairment: results from the cardiovascular health study. Jama. Sep 25. 2002;288(12):1475-1483. [pmid: 12243634].
21 Lyketsos CG, Steinberg M, Tschanz JT, Norton MC, Steffens DC, Breitner JC. Mental and behavioral disturbances in dementia: findings from the Cache County Study on Memory in Aging. Am J Psychiatry. May. 2000;157(5):708-714. [pmid: 10784462].
22 Lopponen M, Raiha I, Isoaho R, Vahlberg T, Kivela SL. Diagnosing cognitive impairment and dementia in primary health care -- a more active approach is needed. Age Ageing. Nov. 2003;32(6):606-612. [pmid: 14600001].
23 Lazarus LW, Newton N, Cohler B, Lesser J, Schweon C. Frequency and presentation of depressive symptoms in patients with primary degenerative dementia. Am J Psychiatry. Jan. 1987;144(1):41-45. [pmid: 3799838].
24 Hancock P, Larner AJ. Diagnostic utility of the Pittsburgh sleep Quality Index in memory clinics. Int J Geriatr Psychiatry. Mar. 31. 2009.
25 Tractenberg RE, Singer CM, Kaye JA. Symptoms of sleep disturbance in persons with Alzheimer’s disease and normal elderly. J Sleep Res. Jun. 2005;14(2):177-185. [pmid: 15910515].
26 Giron MS, Forsell Y, Bernsten C, Thorslund M, Winblad B, Fastbom J. Sleep problems in a very old population: drug use and clinical correlates. J Gerontol A Biol Sci Med Sci. Apr. 2002;57(4):M236-240. [pmid: 11909889].
27 Marion MH, Qurashi M, Marshall G, Foster O. Is REM sleep behaviour disorder (RBD) a risk factor of dementia in idiopathic Parkinson’s disease?. J Neurol. Feb. 2008;255(2):192-196. [pmid: 18217187].
28 Allan LM, Ballard CG, Burn DJ, Kenny RA. Prevalence and severity of gait disorders in Alzheimer’s and non-Alzheimer’s dementias. J Am Geriatr Soc. Oct. 2005;53(10):1681-1687. [pmid: 16181166].
29 O’Keeffe ST, Kazeem H, Philpott RM. Gait disturbance in Alzheimer’s disease: A clinical study. Age Ageing. 1996;25:313-316. [pmid: 8831878].
30 Waite LM, Broe GA, Creasey H, Grayson D, Edelbrock D, O’Toole B. Neurological signs, aging, and the neurodegenerative syndromes. Arch Neurol. Jun. 1996;53(6):498-502. [pmid: 8660150].
31 Huff FJ, Boller F, Lucchelli F, Querriera R, Beyer J, Belle S. The neurologic examination in patients with probable Alzheimer’s disease. Arch Neurol. Sep. 1987;44(9):929-932. [pmid: 3619712].
32 Lee AY, Jeong SH, Choi BH, Sohn EH, Chui H. Pulse pressure correlates with leukoaraiosis in Alzheimer disease. Arch Gerontol Geriatr. Mar–Apr. 2006;42(2):157-166. [pmid: 16139378].
33 Brown LB, Ott BR, Papandonatos GD, Sui Y, Ready RE, Morris JC. Prediction of on-road driving performance in patients with early Alzheimer’s disease. J Am Geriatr Soc. Jan. 2005;53(1):94-98. [pmid: 15667383].
34 Jonker C, Geerlings MI, Schmand B. Are memory complaints predictive for dementia? A review of clinical and population-based studies. Int J Geriatr Psychiatry. Nov. 2000;15(11):983-991. [pmid: 11113976].
35 Jungwirth S, Fischer P, Weissgram S, Kirchmeyr W, Bauer P, Tragl KH. Subjective memory complaints and objective memory impairment in the Vienna-Transdanube aging community. J Am Geriatr Soc. Feb. 2004;52(2):263-268. [pmid: 14728638].
36 Tobiansky R, Blizard R, Livingston G, Mann A. The Gospel Oak Study stage IV: the clinical relevance of subjective memory impairment in older people. Psychol Med. Jul. 1995;25(4):779-786. [pmid: 7480455].
37 St John P, Montgomery P, St John P, Montgomery P. Is subjective memory loss correlated with MMSE scores or dementia?. J Geriatr Psychiatry Neurol. Jun. 2003;16(2):80-83. [pmid: 12801156].
38 Jungwirth S, Weissgram S, Zehetmayer S, Tragl KH, Fischer P. VITA: subtypes of mild cognitive impairment in a community-based cohort at the age of 75 years. Int J Geriatr Psychiatry. May. 2005;20(5):452-458. [pmid: 15852463].
39 Lam LC, Lui VW, Tam CW, et al. Subjective memory complaints in Chinese subjects with mild cognitive impairment and early Alzheimer’s disease. Int J Geriatr Psychiatry. Sep. 2005;20(9):876-882. [pmid: 16116581].
40 Chong MS, Chin JJ, Saw SM, et al. Screening for dementia in the older Chinese with a single question test on progressive forgetfulness. Int J Geriatr Psychiatry. May. 2006;21(5):442-448. [pmid: 16676292].
41 Grut M, Jorm AF, Fratiglioni L, Forsell Y, Viitanen M, Winblad B. Memory complaints of elderly people in a population survey: variation according to dementia stage and depression. J Am Geriatr Soc. Dec. 1993;41(12):1295-1300. [pmid: 8227910].
42 Purser JL, Fillenbaum GG, Wallace RB, Purser JL, Fillenbaum GG, Wallace RB. Memory complaint is not necessary for diagnosis of mild cognitive impairment and does not predict 10-year trajectories of functional disability, word recall, or short portable mental status questionnaire limitations. J Am Geriatr Soc. Feb. 2006;54(2):335-338. [pmid: 16460388].
43 Crooks VC, Buckwalter JG, Petitti DB, Brody KK, Yep RL. Self-reported severe memory problems as a screen for cognitive impairment and dementia. Dementia. 2005;4(4):539-551.
44 Tierney MC, Szalai JP, Snow WG, Fisher RH. The prediction of Alzheimer disease. The role of patient and informant perceptions of cognitive deficits. Arch Neurol. May. 1996;53(5):423-427. [pmid: 8624217].
45 McGlone J, Gupta S, Humphrey D, Oppenheimer S, Mirsen T, Evans DR. Screening for early dementia using memory complaints from patients and relatives. Arch Neurol. Nov. 1990;47(11):1189-1193. [pmid: 2241616].
46 Galvin JE, Roe CM, Xiong C, et al. Validity and reliability of the AD8 informant interview in dementia. Neurology. Dec 12. 2006;67(11):1942-1948. [pmid: 17159098].
47 Galvin JE, Roe CM, Coats MA, et al. Patient’s rating of cognitive ability: using the AD8, a brief informant interview, as a self-rating tool to detect dementia. Arch Neurol. May. 2007;64(5):725-730. [pmid: 17502472].
48 Cummings JL, Mega M, Gray K, Rosenberg-Thompson S, Carusi DA, Gornbein J. The Neuropsychiatric Inventory: comprehensive assessment of psychopathology in dementia. Neurology. Dec. 1994;44(12):2308-2314. [pmid: 7991117].
49 McKhann G, Drachman D, Folstein M, Katzman R, Price D, Stadlan EM. Clinical diagnosis of Alzheimer’s disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer’s Disease. Neurology. Jul. 1984;34(7):939-944. [pmid: 6610841].
50 Katzman R, Brown T, Fuld P, Peck A, Schechter R, Schimmel H. Validation of a short Orientation-Memory-Concentration Test of cognitive impairment. Am J Psychiatry. Jun. 1983;140(6):734-739. [pmid: 6846631].
51 Boustani M, Peterson B, Hanson L, et al. Screening for dementia in primary care: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Jun 3. 2003;138(11):927-937. [pmid: 12779304].
52 Fillenbaum G, Heyman A, Williams K, Prosnitz B, Burchett B. Sensitivity and specificity of standardized screens of cognitive impairment and dementia among elderly black and white community residents. J Clin Epidemiol. 1990;43(7):651-660. [pmid: 2370572].
53 Stuss DT, Meiran N, Guzman DA, Lafleche G, Willmer J. Do long tests yield a more accurate diagnosis of dementia than short tests? A comparison of 5 neuropsychological tests. Arch Neurol. Oct. 1996;53(10):1033-1039. [pmid: 8859066].
54 Davous P, Lamour Y, Debrand E, Rondot P. A comparative evaluation of the short orientation memory concentration test of cognitive impairment. J Neurol Neurosurg Psychiatry. Oct. 1987;50(10):1312-1317. [pmid: 3681309].
55 Costa PT Jr, Williams TF, Somerfield MR, Albert MS, Nutters NM, Folstein MF, et al. Recognition and Initial Assessment of Alzheimer’s Disease and Related Dementias. Clinical Practice Guideline no. 19. Rockville, MD. U.S. Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research. AHCPR Publication no. 97-0702. 1996.
56 Brodaty H, Pond D, Kemp NM, et al. The GPCOG: a new screening test for dementia designed for general practice. J Am Geriatr Soc. Mar. 2002;50(3):530-534. [pmid: 11943052].
57 Basic D, Khoo A, Conforti D, et al. Rowland Universal Dementia Assessment Scale, Mini-Mental State Examination and General Practitioner Assessment of Cognition in a multicultural cohort of community-dwelling older persons with early dementia. Australian Psychologist. 2009;44(1):40-53.
58 Borson S, Scanlan JM, Chen P, Ganguli M. The Mini-Cog as a screen for dementia: validation in a population-based sample. J Am Geriatr Soc. Oct. 2003;51(10):1451-1454. [pmid: 14511167].
59 Borson S, Scanlan JM, Watanabe J, Tu SP, Lessig M. Simplifying detection of cognitive impairment: comparison of the Mini-Cog and Mini-Mental State Examination in a multi-ethnic sample. J Am Geriatr Soc. May. 2005;53(5):871-874. [pmid: 15877567].
60 Kaufer DI, Williams CS, Braaten AJ, Gill K, Zimmerman S, Sloane PD. Cognitive screening for dementia and mild cognitive impairment in assisted living: comparison of 3 tests. J Am Med Dir Assoc. Oct. 2008;9(8):586-593. [pmid: 19083293].
61 Smith T, Gildeh N, Holmes C. The Montreal Cognitive Assessment: validity and utility in a memory clinic setting. Can J Psychiatry. May. 2007;52(5):329-332. [pmid: 17542384].
62 Luis CA, Keegan AP, Mullan M. Cross validation of the Montreal Cognitive Assessment in community dwelling older adults residing in the Southeastern US. Int J Geriatr Psychiatry. 2009;24(2):197-201. [pmid: 18850670].
63 Nasreddine ZS, Phillips NA, Bedirian V, et al. The Montreal Cognitive Assessment, MoCA: a brief screening tool for mild cognitive impairment. J Am Geriatr Soc. Apr. 2005;53(4):695-699. [pmid: 15817019].
64 Tariq SH, Tumosa N, Chibnall JT, Perry MH 3rd, Morley JE. Comparison of the Saint Louis University mental status examination and the mini-mental state examination for detecting dementia and mild neurocognitive disorder--a pilot study. Am J Geriatr Psychiatry. Nov. 2006;14(11):900-910. [pmid: 17068312].
65 Kokmen E, Naessens JM, Offord KP. A short test of mental status: description and preliminary results. Mayo Clin Proc. Apr. 1987;62(4):281-288. [pmid: 3561043].
66 Kokmen E, Smith GE, Petersen RC, Tangalos E, et al. The Short Test of Mental Status: Correlations with standardized psychometric testing. Arch Neurol. Jul. 1991;48(7):725-728. [pmid: 1859300].
67 Holsinger T, Deveau J, Boustani M, Williams JW Jr. Does this patient have dementia?. Jama. Jun 6. 2007;297(21):2391-2404. [pmid: 17551132].
68 Borson S, Scanlan J, Brush M, Vitaliano P, Dokmak A. The mini-cog: a cognitive ‘vital signs’ measure for dementia screening in multi-lingual elderly. Int J Geriatr Psychiatry. Nov. 2000;15(11):1021-1027. [pmid: 11113982].
69 Blessed G, Tomlinson BE, Roth M. The association between quantitative measures of dementia and of senile change in the cerebral grey matter of elderly subjects. Br J Psychiatry. Jul. 1968;114(512):797-811. [pmid: 5662937].
70 Froehlich TE, Bogardus ST Jr, Inouye SK. Dementia and race: are there differences between African Americans and Caucasians?. J Am Geriatr Soc. Apr. 2001;49(4):477-484. [pmid: 11347796].
71 Lourenco RA, Filho Ribeiro ST. The accuracy of the Mini-Cog in screening low-educated elderly for dementia. J Am Geriatr Soc. Feb. 2006;54(2):376-377. author reply 377–378. [pmid: 16460402].
72 Borson S, Scanlan JM. Response to Drs. Lourenco and Ribeiro Filho. J Am Geriatr Soc. Feb. 2006;54(2):377-378.
73 Nasreddine Z. The Montreal Cognitive Assessment - MoCA. http://www.mocatest.org/. Accessed Feb 1, 2010.
74 Boustani M, Peterson B, Hanson L. Screening for dementia Systematic evidence review. US Preventive Services Task Force, Agency for Healthcare Research and Quality. Rockville, MD. http://www.ahrq.gov/clinic/uspstf/uspsdeme.htm. 2003.
75 Callahan CM, Unverzagt FW, Hui SL, et al. Six-item screener to identify cognitive impairment among potential subjects for clinical research. Medical Care. Sep. 2002;40(9):771-781. [pmid: 12218768].
76 Hall KS, Hendrie HC, Brittain HM, et al. The development of a dementia screening interview in two distinct languages. Int J Meth Psychiatric Res. 1993;3:1-28.
77 Comijs HC, Deeg DJH, Dik MG, Twisk JWR, Jonker C. Memory complaints; the association with psycho-affective and health problems and the role of personality characteristics: A 6-year follow-up study. J Affect Disord. 2002;72(2):157-165. [pmid: 12200206].
78 Park MH, Min JY, Min HY, Lee HJ, Lee DH, Song MS. Subjective memory complaints and clinical characteristics in elderly Koreans: A questionnaire survey. International Journal of Nursing Studies. 2007;44(8):1400-1405. [pmid: 16919634].
79 Blazer DG, Hays JC, Fillenbaum GG, Gold DT. Memory complaint as a predictor of cognitive decline: a comparison of African American and White elders. J Aging Health. May. 1997;9(2):171-184. [pmid: 10182402].
80 Jorm AF. Methods of screening for dementia: a meta-analysis of studies comparing an informant questionnaire with a brief cognitive test. Alzheimer Dis Assoc Disord. Sep. 1997;11(3):158-162. [pmid: 9305501].
81 Koss E, Patterson MB, Ownby R, Stuckey JC, Whitehouse PJ. Memory evaluation in Alzheimer’s disease. Caregivers’ appraisals and objective testing. Arch Neurol. Jan. 1993;50(1):92-97. [pmid: 8418807].
82 Shen J, Gao S, Unverzagt FW, et al. Validation analysis of informant’s ratings of cognitive function in African Americans and Nigerians. Int J Geriatr Psychiatry. Jul. 2006;21(7):618-625. [pmid: 16802282].
83 Milne A, Culverwell A, Guss R, Tuppen J, Whelton R. Screening for dementia in primary care: a review of the use, efficacy and quality of measures. Int Psychogeriatr. Oct. 2008;20(5):911-926. [pmid: 18533066].