# DISCUSSION

## SIGNS AND SYMPTOMS OF DEMENTIA

Efforts to improve dementia case finding in general practice settings may be hampered by the protean manifestations of the disease, and the low sensitivity of many of the signs and symptoms encountered in practice. The utility of these signs and symptoms in effectively triaging patients for further diagnostic assessment would depend on the relative value placed on reducing false positive findings as compared to increasing dementia detection rates and reducing false negative rates. Determining the long-term benefits and harms of earlier and increased rates of dementia detection has been debated in the literature, but is largely beyond the scope of this review.

All of the signs and symptoms we evaluated were poorly sensitive in detecting mild dementia. This may reflect inter-individual variation in clinical manifestations of dementia, variations in the methods for detecting these signs and symptoms, or simply a reflection of the almost subclinical nature of early dementia.

The best studied of these symptoms are subjective memory complaints (SMC), which are theoretically attractive as a very brief initial assessment method in general practice settings. However, the presence of self-reported SMC does not correlate well with existing dementia. On the other hand, most cognitively intact persons do not have SMC, which may mean that in low prevalence settings, lack of SMC may be useful in identifying patients who could forego further dementia assessment. One potential consequence of routinely eliciting SMC in general practice patients is the likely high rate of false positives. If the finding of SMC would trigger further evaluation for dementia, this could lead to significant time pressures in general practice settings given that many of the “brief” assessment methods require 2 to 10 minutes to complete.

Of note, several large prospective cohort studies in different populations have found that elicited SMC are very common but of questionable significance, as they may not predict future cognitive decline.77–79 Rather, studies have suggested self-reported SMC are associated with depression, anxiety, physical health and personality traits.18, 45, 77

Informant-reported memory complaints may better differentiate demented from non-demented individuals18 and may be a promising area of inquiry for future case-finding approaches. The AD8 may be a promising very brief assessment instrument based partly on informant-reported memory complaints.46 A number of additional studies have found that caregivers of demented patients are reliably able to assess their cognitive deficits.45, 80–82 However, most of these studies have evaluated the use of longer questionnaires which may take some time to administer, and function almost as a proxy dementia screening tool.

Some neuropsychiatric symptoms such as apathy, hallucinations, and delusions are relatively uncommon in healthy elderly people and may suggest the need for further evaluation when present. Depression and anxiety, on the other hand, do not seem to be useful in distinguishing demented from non-demented individuals.

## BRIEF MEASURES OF COGNITIVE FUNCTION AVAILABLE TO VA

The 6 measures available in VA all test for memory impairment, while apraxia and executive function (including a clock drawing test) are assessed in all measures except the BOMC. The assessment of other cognitive domains such as orientation, abstraction, and aphasia varies among the 6 measures (Table 5). A 2007 review by Holsinger, et al. discusses the cognitive domains in the DSM-IV criteria for dementia, and describes tasks used to assess each domain.67

Among the 6 tests, the Mini-Cog has the shortest administration time (2 to 4 minutes), and has been studied in a large population sample as well as in multi-ethnic samples. Sensitivity and specificity were high in 2 studies, while poor specificity in a third study may have resulted from inclusion of subjects with MCI.

The SLUMS examination had very high sensitivity and specificity in a VA population, and it allows for adjustment for education. However, the SLUMS has a longer administration time (approximately 7 minutes) compared with other tests, and has only been evaluated in 1 study.

The other 4 tests had various strengths and limitations. The STMS had high sensitivity and specificity in a primary care setting, but has been evaluated in only 2 studies. The GPCOG is unique in that it allows for the input of an informant; however, the specificity of the informant section by itself was low (49–66%). The BOMC was evaluated in a bi-racial population sample, and was found to misclassify more blacks than whites as impaired. Specificity varied widely among studies of the BOMC. The MoCA has the longest administration time among the 6 tests, and had low specificity (35–50%) in 2 of 3 studies.

## LIMITATIONS

Our review does not address the relative value of various signs or symptoms in predicting future dementia. Also, because we excluded studies involving only patients with mild cognitive impairment (MCI) and because few included studies enrolled patients with very mild or very early dementia, these results may not be readily applicable to case-finding approaches designed to detect those patients with the earliest manifestations of disease.

The scope of this review was limited to the 6 brief cognitive measures identified as priorities for VA. There are many other cognitive measures available that are not covered in this review. Few studies have assessed the 6 instruments in VA populations, and though some of the study populations may be similar to VA populations, applicability to VA settings cannot be directly assumed. The adverse consequences of the 6 cognitive measures have not been studied.

## FUTURE RESEARCH RECOMMENDATIONS

### Consequences of expanded case-finding efforts

The utility and consequences of a targeted case-finding approach in VA primary care settings should be assessed. For instance, the utility of routinely asking about memory problems followed by a brief dementia assessment method in patients with a positive response should be studied. It would be critical in such a study to carefully assess both the rate and consequences of false-positive results, as well as the cost and time used to find one additional confirmed case of dementia.

The psychologic, financial, and quality of life consequences of both true- and false-positive dementia diagnoses should be more rigorously evaluated. High refusal rates of screening and diagnostic workup indicate the need for further research to understand the psychological burden associated with cognitive tests and assessment for dementia.

### The role of caregivers in evaluating patients for dementia

The value of routinely asking patient caregivers about memory problems as an alternative to patient-reported memory complaints should be studied as well. Given a limited amount of literature suggesting informant characteristics may impact the reliability of informant report,82 future studies of informant-administered instruments should also analyze the impact of the informant’s relationship to the patient on the diagnostic utility of the instrument.

The reliability and validity of very brief informant assessment instruments such as the AD8 should be evaluated in different settings.

### Evaluating combinations of signs and symptoms

Many of the signs and symptoms we examined were reported in isolation. Studies that examine the diagnostic utility of groups of signs and symptoms should be conducted.

### Provider response to self-reported subjective memory complaints

Though the value of routine screening for dementia remains an active area of debate, subjective memory complaints are common enough that future studies, quality improvement, and education improvement efforts should ensure primary care providers are trained to feel comfortable having sensitive and holistic discussions with patients and their caregivers about memory loss. Studies should also address whether an assessment negative for dementia following a subjective memory complaint can be therapeutically useful.

### Dementia and depression

Rates and consequences of the misclassification of dementia as depression (and vice versa) should be further studied.

### Operating characteristics of the cognitive measures available in VA

The SLUMS and STMS tests have not been widely studied. Further studies are needed to assess the operating characteristics of these tests in various settings.

Of the 6 measures, only the BOMC and Mini-Cog have been evaluated in multi-ethnic samples. Further studies are needed to assess whether race or language biases affect the performance of the other cognitive measures.

### Clinical utility of the cognitive measures available in VA

The perceived clinical utility of the GPCOG and Mini-Cog was examined in a narrative review and found to be equally high.83 A similar survey among VA providers would be useful for determining preferences and utilities of the 6 measures available in VA. Because clinicians may need to use these assessment tools in busy primary care practices, studies should assess the instruments’ ease of use, time to completion, and adverse effects in real-world VA settings.